# METHODS

## Literature search

A systematic literature search was performed to identify relevant articles on PET scans and thyroid cancer. The search was supplemented by articles in reference lists of relevant articles and reviews.

A Medline literature search was performed on Sept 28, 2001 (1966 – September Week 3 2001) to capture primary studies that investigated the use of PET scans for thyroid cancer. The Medline search was supplemented by searches in Biosis and CancerLIT. See Table 1 for search strategy used. The search strategy found studies on thyroid, thyroid cancer or thyroid cancer markers, which were also on PET and related technologies. The goal of the search was to be highly sensitive, to capture as many relevant articles as possible. Relevant keywords from articles found from preliminary searches (eg, Medline registry numbers for FDG) were added to broaden the search results. The search was limited to English-language studies of human subjects. Studies prior to 1980 were excluded as PET did not exist prior to this.

Table 1 Search strategies

# | Search History | Results | Description
1 | exp thyroid gland/ or thyroid gland.af | 41537 | Thyroid, Thyroid cancer, and Thyroid cancer markers
2 | exp thyroid neoplasms/ or thyroid neoplasm.af | 21267 | Thyroid, Thyroid cancer, and Thyroid cancer markers
3 | thyro$.af. | 187518 | Thyroid, Thyroid cancer, and Thyroid cancer markers
4 | (cancer$ or neoplasm$ or tumo$).af. | 2090496 | Thyroid, Thyroid cancer, and Thyroid cancer markers
5 | exp thyroglobulin/ or thyroglobulin.af | 9496 | Thyroid, Thyroid cancer, and Thyroid cancer markers
6 | exp calcitonin/ or calcitonin.af. | 23125 | Thyroid, Thyroid cancer, and Thyroid cancer markers
7 | 1 or 2 or (3 and 4) or 5 or 6 | 102253 | Thyroid, Thyroid cancer, and Thyroid cancer markers
8 | (positron or pet or fdg).af. | 32688 | FDG PET scanning and related diagnostic tests
9 | exp fludeoxyglucose f 18/ or fludeoxyglucose.af. | 3686 | FDG PET scanning and related diagnostic tests
10 | exp radionuclide imaging/ or radionuclide imaging.af. | 57655 | FDG PET scanning and related diagnostic tests
11 | exp diagnostic techniques, radioisotope/ | 132768 | FDG PET scanning and related diagnostic tests
12 | exp tomography, emission-computed/ | 27411 | FDG PET scanning and related diagnostic tests
13 | (spect or single photon emission).af. | 20192 | FDG PET scanning and related diagnostic tests
14 | (63503-12-8 or 154-17-6).rn. | 11366 | FDG PET scanning and related diagnostic tests
15 | 8 or 9 or 10 or 11 or 12 or 13 or 14 | 170618 | FDG PET scanning and related diagnostic tests
16 | 7 and 15 | 4461 | PET and Thyroid
17 | Limit 16 to English language | 3276
18 | Limit 17 to human | 2408
19 | Limit 18 to yr=1980–2001 | 1392

The abstracts and titles from the literature search were screened for potentially relevant articles. We retrieved and reviewed relevant primary and review articles. We extracted data from primary studies of the diagnostic performance or clinical outcomes of PET for previously treated thyroid cancer.

## Thyroid cancer classification

Studies were divided into those that evaluated subjects with epithelial thyroid cancer and those that evaluated subjects with medullary thyroid cancer. Studies that evaluated subjects with both tumor types were included in both sections. Among studies of epithelial tumors, subjects that were reported to have follicular, papillary, mixed follicular-papillary, differentiated, well-differentiated, or Hürthle cell cancers were analyzed together as differentiated thyroid cancer. Those with Hürthle cell tumors were also analyzed separately. Subjects with other epithelial tumors that may concentrate iodine poorly were analyzed separately. All subjects with medullary cancer were analyzed together.

## Eligibility criteria

Studies of diagnostic performance or clinical effect of PET for all types of thyroid cancer were included. Diagnostic studies had to evaluate the test performance of PET to differentiate subjects with metastatic thyroid cancer from those without metastatic disease; sufficient data were required to estimate PET sensitivity and specificity. Studies had to include either data on final diagnosis (outcome) or on disposition of subjects based on lesion histology or clinical follow-up. Thus diagnostic studies that reported only the positive and negative rate of PET or only compared the rate of positive PET to positive WBS or other imaging tests were excluded. No study was rejected based on the reference standards used.

Studies of differentiated thyroid cancer had to evaluate at least 10 subjects. While it would have been preferable to include only studies that included at least 10 subjects with and 10 subjects without metastatic disease, this would have resulted in having too few qualifying studies. Because only one study of PET for other thyroid cancers (medullary, anaplastic) included more than 10 subjects and because of the small total number of such studies, all were included, regardless of sample size. Review articles of PET and thyroid cancer were examined for additional references and for background information.

In general, only studies that reported either test performance data or clinical outcome data on PET specific to samples of subjects who were within the populations of interest were included. These included subjects with either 1) treated differentiated thyroid cancer, elevated Tg or anti-Tg antibody, and negative WBS, 2) treated medullary thyroid cancer, elevated calcitonin or CEA, and negative standard imaging, or 3) untreated differentiated thyroid cancer types that commonly do not take up radioiodine. We did not define “standard imaging” a priori, but used each study’s definitions as implied by what imaging test results were reported. Studies reporting data on any rare form of thyroid cancer, regardless of prior testing, were included. Studies were not excluded based on any quality criteria.

To focus on the value of PET in patients with differentiated thyroid cancer in the setting of elevated marker and negative WBS, we ignored the results of imaging tests for differentiated cancer other than WBS and PET (when reported). While in clinical practice PET or other imaging studies may not be necessary for a patient with a negative WBS but a positive bone scan, we aimed to make our findings as generalizable as possible by not considering less commonly used imaging tests for differentiated cancer. Furthermore, few studies sufficiently reported on other imaging tests to allow us to summarize only those subjects with all imaging tests negative.

## Estimating overall test performance

For analysis of differentiated thyroid cancer studies (for which there were sufficient data), we used two different methods to summarize the test performance of PET: plotting studies in receiver operating characteristics (ROC) space, and separately averaged sensitivity and specificity values across studies. For analysis of medullary thyroid cancer studies (for which there were minimal data), we calculated a combined test performance by simply adding the data across studies.

In the ROC analysis, each study provides a pair of sensitivity and specificity values. Individual studies are plotted with the sensitivity on the x-axis and 100%-specificity on the y-axis. Studies with better test performance (higher sensitivity and specificity) will fall closer to the upper left corner.

To determine an estimate of overall test performance for differentiated thyroid cancer we combined test performance data to calculate average sensitivity and specificity across studies. We used a random effects model which weights studies by both within-study variation (sampling error) and between-study variation (true treatment-effect differences). It gives wider confidence intervals than the fixed effects model, which includes only within-study variation, and is thus a more conservative estimate of test performance. In addition to error due to chance, the random effects model also accounts for error due to heterogeneity among studies. Combined sensitivity and specificity are calculated independently.

When each value is combined separately, sensitivity and specificity tend to underestimate the true sensitivity and specificity. While this method treats sensitivity and specificity as independent, in reality, the two are inversely related to each other; as the test threshold is varied to increase sensitivity, specificity falls, and vice versa. Furthermore, the value of the combined estimates should be interpreted with caution in cases where there is wide variability in test results from different studies. The independently combined estimates using the random effects model may nonetheless be useful estimates of the average test performance.