# INTRODUCTION

## Evaluation of Patients Suspected to Have Metastatic Thyroid Cancer

Patients with epithelial thyroid cancer or medullary thyroid cancer require evaluation of the extent of disease in order to determine management. Prior to definitive treatment, staging occurs to determine the spread of the cancer. After initial treatment patients are generally followed for possible local recurrence or distant metastasis of disease. Positron emission tomography (PET) has been proposed for use in both initial and post-treatment staging of thyroid cancer.

Epithelial thyroid cancers are divided into differentiated carcinomas (papillary and follicular) and anaplastic carcinomas. Most differentiated carcinomas secrete thyroglobulin (Tg) and take up iodine. Thus Tg level and ^131^I whole body scintigraphy (WBS) are commonly used to look for metastases of this tumor. (1) However, metastases of differentiated thyroid cancer are less efficient at iodine uptake than normal thyroid tissue and less than 50% of papillary and about 33% of follicular thyroid metastases can be imaged with radioactive iodine. (2) Certain subtypes of differentiated carcinomas, including Hürthle cell tumors, are less likely to take up iodine. (2) The evaluation of patients with poorly differentiated insular, tall cell and columnar variants of papillary cancer, and anaplastic (undifferentiated) thyroid cancers is complicated by the lack of tumor markers or variability of radioisotope uptake. (3; 4)

For patients with medullary thyroid cancer, calcitonin and/or carcinoembryonic antigen (CEA) levels are followed to indicate the presence of metastatic disease. (1) However, further evaluation of patients with elevated calcitonin levels following operative resection is challenging since in many patients the use of multiple imaging modalities fails to localize the metastatic disease. (1)

Patients with biochemical evidence of metastatic disease generally have imaging tests performed to localize metastases. If the imaging test -- WBS for differentiated thyroid cancer or computed tomography, somatostatin receptor scintigraphy (SRS), magnetic resonance imaging, ultrasonography or other tests for medullary or less well differentiated tumors -- is non-diagnostic, there is no consensus on the next level of appropriate test. PET has been proposed as a highly accurate test to detect metastatic thyroid cancer.

PET is a nuclear medicine imaging technique that uses radiopharmaceuticals, typically a radionuclide-labeled analogue of glucose, 2-[^18^F] fluoro-2-deoxy-D-glucose (FDG), to detect abnormal metabolic activity within the body. Since malignant tumors usually have increased cellular metabolism, and thus increased glucose metabolism, PET is able to localize malignant tissue. By providing information on function and metabolism, PET may complement traditional imaging modalities such as plain-film radiography, computed tomography (CT) and magnetic resonance imaging (MRI), which provide anatomical information of both normal and abnormal structures. In addition to being able to distinguish benign from malignant processes based on differences in biological activity, PET has the advantage of being able to examine the whole body for both primary and metastatic disease in a single procedure. (5)

PET has the disadvantages of being expensive and not commonly available. Furthermore, FDG PET will not detect tumors that do not take up glucose, must be used with care in diabetics, and is unlikely to detect metastatic brain masses (due to the high uptake of glucose by brain tissue).

FDG PET has been proposed for use in the evaluation of patients with evidence of metastatic differentiated and medullary thyroid cancer with non-diagnostic imaging tests, as well as in the initial staging of thyroid cancer prior to treatment. A HCFA (now CMS) public hearing was held in 2000 to discuss coverage of PET for a broad range of uses, including thyroid cancer. CMS is currently evaluating the use of PET for thyroid cancer and has requested assistance from AHRQ in evaluating the available evidence.

Specific questions of addressed are:

1. What is the test performance of FDG PET for localization or staging of previously treated thyroid cancer suspected to be metastatic (due to elevated biochemical marker or to tumor type) for which standard imaging modalities (scintigraphy, ultrasonography, computed tomography, magnetic resonance imaging) have failed to localize metastatic lesions or are thought not to be helpful to locate metastatic disease (such as Hürthle cell thyroid cancer, histological variants of thyroid cancer such as tall-cell or insular subtypes, and other poorly differentiated thyroid cancers which may take up iodine poorly)?
2. What is the evidence that FDG PET affects health outcomes (survival, cancer recurrence, quality of life) or alters management when used for localization or staging of previously treated thyroid cancer suspected to be metastatic for which standard imaging modalities have failed to localize metastatic lesions or are thought not to be helpful to locate metastatic disease?

A third question related to the utility of PET in the initial staging of thyroid cancers known to concentrate iodine poorly. This topic was not addressed because only one study, which reported on only 1 subject with Hürthle cell cancer, addressed this issue. (6