# DISCUSSION

## Limitations due to study quality

The quality of the studies and the value of their reported data are limited by a number of factors. Only two studies were prospective in design and included only subjects with biochemical evidence of metastasis and negative imaging tests. Of these only one met minimal criteria to reliably estimate test performance (10 subjects in both metastatic disease and no metastatic disease arms). Most other studies were retrospective case series. Some were clearly biased samples of the authors’ experiences with PET. In addition most studies included mixed populations of subjects with different disease types and different underlying likelihood of metastatic disease. No study of differentiated thyroid cancer included a sub-analysis of the value of PET in patients with negative WBS and other standard imaging tests (eg, CXR, CT, MRI, US). Studies of medullary thyroid cancer used widely different batteries of “standard” imaging tests prior to PET.

Most studies did not limit eligible subjects to those for whom PET is most likely to be of value, eg, those at higher risk of metastasis based on biochemical tests (Tg or calcitonin) but who have a negative imaging work-up. Therefore much of the data for this report are based on sub-group analyses or, more frequently, individual subjects from broader studies who fit the criteria of this report. These data, in general, are unreliable as they rely on incomplete and unclear reporting. Furthermore, no study explicitly examined the incremental value of PET over other imaging tests.

Furthermore, most studies had small sample sizes. Only two studies of differentiated thyroid cancer had minimally sufficient sample sizes for potentially reliable estimates of both sensitivity and specificity. For studies of medullary cancer, no study had at least 10 subjects who met criteria for this report. Studies that reported on rarer tumors were all too small to provide reliable estimates of test performance.

Blinding of PET interpreters to clinical data was infrequent. Only five studies reported that blinding occurred. Unblinded studies are less reliable since the interpretation of the PET scan may in part be based on other clinical data. This is especially the case for these studies as many included subjects had other positive imaging tests. This problem is further compounded by the fact that most studies used vague or qualitative definitions of positive PET scan, such as increased or abnormal FDG uptake. These definitions allow subjective test interpretation that may be more susceptible to bias based on known clinical data. Only rarely did studies used quantitative standardized uptake values (SUV) to define positive tests, but even some of these combined SUV data with qualitative definitions (eg, SUV threshold or abnormal uptake of FDG).

Reference standards (the definition of whether a subject truly has or does not have metastatic disease) were rarely well defined. All studies (except one with no data) used histology from biopsy or surgery to diagnose at least some subjects with positive PET. Some studies also used exploratory surgery to diagnose some subjects with negative PET. Most relied on clinical follow-up to diagnose subjects with negative PET. However, none gave a clear description of how final diagnoses were made clinically. In addition, many relied on other imaging tests and even changes in Tg or calcitonin levels. Some used clinical follow-up to determine a final diagnosis even for some subjects with positive PET. Few studies reported the duration of clinical follow-up. Most of those that did, had short duration of follow-up (less than 3 years). For many studies, the definitions of reference standards were unclear and it was thus difficult to assign subjects as either positive or negative for metastases.

Another source of possible bias is funding source. Of note, no study reported the source of study funding. While this is a common omission, it is of particular concern for the evaluation of a technology that has a high capital expense, a high per test cost, and that is not routinely available or paid for.

Finally, there was considerable duplication of data due to multiple publications on the same study samples. While most of these duplications were easy to discover, the largest study most likely includes many subjects from multiple previously reported studies. The study neither acknowledged the other studies nor clearly stated the source of their study sample.

## Findings

Test performance of FDG PET for localization or staging of previously treated thyroid cancer suspected to be metastatic for which standard imaging modalities have failed to localize metastatic lesions or are thought not to be helpful to locate metastatic disease.

Eleven studies with at least 10 subjects each (total of 244 subjects) reported test performance data in subjects with treated differentiated thyroid cancer, elevated Tg, and negative WBS. The largest study included 65 subjects who met these criteria. (13)Six studies of medullary thyroid cancer reported test performance data on between 1 and 6 subjects. A total of 17 subjects were included.

Data on relatively rare tumor types that may have variable secretion of tumor markers (eg, Tg) and variable uptake of iodine (for WBS) are sparse. Nine studies reported data on subjects with Hürthle cell tumors (49 subjects in seven studies), poorly differentiated tumors (28 subjects in one study), anaplastic tumors (6 subjects in two studies), eosinophilic tumors (4 subjects in one study), and tall cell papillary cancer (1 subject).

Only two studies, Grunwald (1999) and Helal (2001), reported on at least 10 subjects with and 10 without metastatic disease, the minimum number of subjects needed to provide minimally reliable estimates of both sensitivity and specificity. Grunwald (1999) is the larger study and the only study with a large number of subjects without metastatic disease, but it suffers from being a retrospective study that apparently combined previously reported patients from multiple centers, not having a predetermined definition of a reference standard (whether subjects actually have metastatic disease or not), not blinding PET interpreters from clinical data, and not focusing on subjects with elevated Tg and negative WBS. The sample of subjects is therefore likely to be heterogeneous and the applicability of the findings may be questionable. While the study appears to be multicenter, no analysis is reported accounting for possible differences among centers or PET scanners. The evaluation of subjects with marker of disease, but no other evidence of metastasis, is only a sub-group analysis of the whole data set. This subgroup also is incompletely defined. All subjects had Tg levels greater than 5 ng/mL, although it is unclear whether this threshold was based on suppressed or non-suppressed conditions. Helal (2001) was of better quality, being a prospective, blinded study with predetermined reference standards and PET interpreter blinding that focused on subjects with treated differentiated thyroid cancer, elevated Tg and negative WBS. While the subjects were consecutively submitted to PET evaluation at one center, it is unclear if the subjects represented a selected sample of subjects who had their primary treatment at various hospitals. The study is relatively small and was barely of sufficient size to give a reliable estimate of specificity (with only 11 subjects without metastatic disease).

The remaining smaller, generally retrospective studies, that did not always have clear reference standards or reporting, found PET sensitivity that ranged from 62% to 100% but specificity that varied over the full range (0% to 100%). For the studies that we were able to combine using the random effects model, including the two larger studies, we found a combined sensitivity of 84% (95% confidence interval 73%–91%) and a pooled specificity of 56% (95% confidence interval 27%–82%). However, given the wide variability of test performance across studies and the extremely small number of subjects without metastatic disease group in some studies, these combined estimates are not reliable and are of questionable value.

Only one study provided test performance data for more than a handful of subjects with Hürthle cell tumors. Grunwald (1999) analyzed 20 subjects with Hürthle cell tumors; no data were provided about Tg level; 2 of the subjects had positive WBS. PET sensitivity to diagnose metastatic disease was 87% and specificity was 100%. Besides the small number of subjects and the mixed population, this analysis suffers from the same problems as discussed above for this paper.

The same study also compared PET test performance of subjects with well differentiated and poorly differentiated tumors (using an unvalidated grading system). Test performance for PET was actually somewhat lower for well-differentiated tumors than poorly differentiated tumors. This was thought to be because well-differentiated tumors are slower growing and less metabolically active (therefore, they would take up less FDG).

Data on the test performance of PET for diagnosis of metastatic disease in patients with medullary cancer, elevated calcitonin and negative standard imaging tests are sparse. Among six studies, the largest included only 6 subjects. No study included more than 1 subject without metastatic disease. Three studies had no subjects without metastatic disease. Therefore no individual study provides any useful information about the test performance of PET for medullary cancer. The ability to make comparisons among studies and to generalize the findings from each study is further limited by the different imaging tests used prior to PET from study to study subject to subject. These imaging tests included CXR, CT, MRI, US and various forms of scintigraphy. No subject was reported to have all tests. Nevertheless, by doing a simple combination of the 17 subjects in these studies, a rough estimate of test performance found sensitivity of 92% and specificity of 50%. However, these values should be treated with skepticism. This method of combining test performance data does not have true validity. Even by broadening the population of interest to all patients with treated medullary cancer and elevated calcitonin, regardless of other imaging test results, the largest study had complete data on only 17 subjects. In contrast to the other much smaller studies, sensitivity was only 76%. All subjects had metastatic disease so specificity could not be calculated. Two patients, however, were excluded because final diagnosis data were not obtained.

Two studies directly compared PET to SRS and DMSA scintigraphy for medullary cancer in 13 subjects. Whereas PET was highly sensitive for localizing metastases, SRS and DMSA scintigraphy were false negative for almost all subjects and lesions.

There were insufficient data in the literature to estimate PET test performance for tumor types other than well-differentiated thyroid cancer, Hürthle cell tumors, or medullary cancer.

### Data on false positive PET scans

Nine studies had 33 subjects with false positive PET scans. Fifteen of these subjects had elevated biochemical markers and negative imaging tests. Overall, 60% of false positive lesions were located in the neck. The only clinically important findings by PET among the lesions false positive for cancer were one case of tuberculosis and one case of fibrous dysplasia of the humerus. At least nine subjects had biopsies or surgery that would not have been done based on other imaging tests, that were negative for clinically important diagnoses. However, assessment of the subjects with false positive PET, and calculation of PET test performance, is limited by the fact that only about half the subjects had histology of the reported false positive lesions. It is likely that a number of the subjects whose diagnoses were based on other imaging tests had true positive PET scans that were unconfirmed.

Effect of FDG PET on health outcomes or clinical management of previously treated thyroid cancer suspected to be metastatic for which standard imaging modalities have failed to localize metastatic lesions or are thought not to be helpful to locate metastatic disease

Data on the effect of PET on patient management or clinical outcomes for patients with treated differentiated thyroid cancer, elevated Tg and negative WBS were reported in seven small studies with a total of 97 subjects. Overall, about 80% of subjects with positive PET scans were reported to have further treatment (surgery, radioiodine ablation, or retinoic acid treatment) based on the PET results. About 20% of subjects had no change in treatment based on PET, not including subjects reported only in a letter for whom PET was explicitly ignored for treatment management. In four studies, one-third of subjects had reported cure of metastatic disease from treatment that was based on PET. However, one study had a mean follow-up duration of only 6 months and two studies did not provide data on follow-up duration.

Data on the effect of PET on patient management or clinical outcomes for patients with treated medullary cancer and elevated calcitonin are limited. One study of 8 subjects with negative standard imaging tests reported that 2 of the subjects had curative surgery based on PET. No follow-up duration was reported. The only study of subjects with medullary cancer that included more than 10 subjects evaluated patients regardless of other imaging test results. The study found that 60% of 15 subjects with positive PET had surgery based on PET. No data were reported on cure rate. Thus, no reliable estimates of the effect of PET on clinical management or outcomes of patients with treated medullary thyroid cancer have been published.

No useful data have been reported on the effect of PET on clinical management or outcomes of patients with other forms of thyroid cancer.

Overall, the published data on test performance and effect on clinical management and outcomes of PET for patients with thyroid cancer, biochemical evidence of metastasis and negative standard imaging tests are sparse and of poor quality. Of 41 published primary articles on PET for diagnosis of metastasis in treated thyroid cancer, only two are sufficiently powered to provide potentially reliable estimates of both sensitivity and specificity for the populations of interest. Both of these studies evaluated patients with differentiated thyroid cancer. No study directly addressed the question of whether the use of PET has an effect on patient management, cure rate and survival. No study reported clear, complete data that could be used to estimate the clinical value of PET for diagnosis of metastatic thyroid cancer.

## In conclusion

- Only two studies reported on at least 10 subjects both with and without metastatic differentiated thyroid cancer who had elevated Tg, and negative WBS. However, poor quality and small sample size limit their reliability
  - A subgroup of 65 subjects in one study found sensitivity = 88% and specificity =100%
  - A second study of 37 subjects found sensitivity = 96% and specificity, based on only 11 subjects, = 73%
  - Nine smaller studies provided unreliable estimates of test performance
    - Sensitivity ranged from 62% to 100%
    - Specificity ranged from 0% to 100%
  - Combined test performance (using a random effects model) of all the studies found sensitivity = 84% (95% confidence interval 73%–91%) and specificity = 56% (95% confidence interval 27%–82%)
    - However, these combined estimates are not similar to any study’s findings and are not reliable due to the variability of test performance across studies and the small study sizes
- No study had sufficient subjects to estimate the test performance of PET for patients with treated medullary cancer, elevated calcitonin and negative standard imaging tests to diagnose metastatic disease
  - The largest such study included only 6 subjects
  - A simple summation of subjects across six studies yielded overall sensitivity = 92% and specificity = 50%.
    - These values are at best preliminary estimates and should not be considered to be accurate or reliable.
- Two studies with 13 subjects with medullary cancer directly compared PET to SRS and DMSA scintigraphy. 12 subjects had 62 confirmed positive lesions on PET. Of these, SRS was positive for only one lesion and DMSA scintigraphy was positive for only two lesions in 2 subjects.
- Little data exist on the test performance of PET for patients with rare forms of thyroid cancer to diagnose metastatic disease
  - One study with 20 subjects with Hürthle cell tumors found sensitivity = 87% and specificity = 100%
  - One study with 28 subjects with poorly differentiated tumors found sensitivity = 76% and specificity = 82%
    - Among 39 subjects with well-differentiated tumors, sensitivity = 66% and specificity = 100%
  - Insufficient data exist to estimate test performance for various rare tumor types
- Nine studies reported 33 subjects with false positive PET
  - 60% had false positive lesions in their neck
  - At least 9 subjects had biopsies or surgery based on PET alone that were negative for clinically important disease
  - 1 subject had tuberculosis and 1 had fibrous dysplasia of the humerus discovered based on otherwise false positive PET
- No study was specifically designed to determine the effect of PET on clinical management or outcomes in patients with treated thyroid cancer, and provided quantitative estimates
- Among six small studies of subjects with treated differentiated thyroid cancer, elevated Tg, and negative WBS, about 80% of subjects had treatment for metastatic disease based on positive PET, about 20% of subjects had no change in management, about one-third had short-term (about 6 month to 3 year) reported cure and one-third had tumor recurrence after treatment (the remainder are not described)
- Only two small studies evaluated effect of PET on clinical management or outcomes in patients with treated medullary cancer, elevated calcitonin and negative standard imaging tests. Three of 9 subjects had surgery and reported cure after PET; no data were provided as to duration of cure
- No data were reported on the effect of PET on clinical management or outcomes in patients with rare forms of thyroid cancer
- Overall, studies on the use of PET for thyroid cancer are small and of poor quality.