# ABBREVIATIONS

af: all fields (Medline)
CEA: carcinoembryonic antigen
cm: centimeter
CMS: Centers for Medicare and Medicaid Services
CT: computed tomography
CXR: chest X-ray (plain radiography)
Diff't'ed: differentiated thyroid cancer
DMSA: ^99m^Tc(V)-dimercaptosuccinic acid scintigraphy
Dx: diagnosis
EJNM: European Journal of Nuclear Medicine
exp: explode (Medline)
F: female
FDG: 2-[18F] fluoro-2-deoxy-D-glucose
FN: false negative
FNA: fine needle aspiration biopsy
FP: false positive
HCFA: Health Care Financing Administration
hr: hour
Inflam: inflamed
IV: intravenous
L: liter
LN: lymph node
M: male
MBq: milliBecqueral
mCI: milliCurie
MDP: ^99m^Tc methylene diphosphonate scintigraphy
MIBI: ^99m^Tc sestamibi scintigraphy
min: minutes
mL: milliliter
MRI: magnetic resonance imaging
MTC: medullary thyroid cancer
N/n: number
ND: no data
ng: nanogram
NMC: Nuclear Medicine Communications
Non-Dx: non-diagnostic
PET: positron emission tomography
Pt: patient
rn: registry number (Medline)
ROC: receiver operating charachteristics
SRS: somatostatin receptor scintigraphy
SUV: standardized uptake value
TB: tuberculosis
Tg: thyroglobulin
TN: true negative
TP: true positive
TSH: thyroid stimulating hormone
US: ultrasonography
WBS: ^131^I whole body scintigraphy
y: years old
yr: year (Medline)
$: wild card (Medline)