# EXECUTIVE SUMMARY

Background. Patients with treated thyroid cancer are followed routinely to look for metastatic disease. For most tumor types, patients can be followed by serum biomarkers, such as thyroglobulin for differentiated cancer or calcitonin for medullary cancer, which indicate the likely recurrence of thyroid cancer. To confirm and localize the tumor recurrence or metastasis an imaging study is used, such as ^131^I scintigraphy (WBS) for differentiated cancer or computed tomography, somatostatin receptor scintigraphy (SRS), or magnetic resonance imaging for medullary cancer. However, these standard imaging tests may be negative in the face of biochemical evidence of metastatic disease. Positron emission tomography (PET) has been proposed as a highly accurate test to detect metastatic disease in this setting. However, PET is expensive, is not commonly available, and may not be sensitive for metabolically inactive tumors.

Questions of interest. 1. What is the test performance of PET for localization or staging of previously treated thyroid cancer suspected to be metastatic for which standard imaging modalities have failed to localize metastatic lesions or are thought not to be helpful to locate metastatic disease? 2. In the same population, what is the evidence that PET affects health outcomes or alters management? 3. What are the test performance and effect on clinical management of PET for initial, pre-treatment, staging of patients differentiated thyroid cancer types that commonly do not take up radioiodine?

Methods. We conducted a comprehensive Medline search for English-language literature. Additional articles were found from references of reviewed articles. Search terms included those related to PET scan and thyroid cancer. Included were studies that reported on diagnostic performance of PET or clinical outcomes of subjects who had PET. Studies of differentiated thyroid cancer with fewer than 10 subjects were excluded. Studies of medullary and other rare thyroid tumors were included regardless of sample size due to the scarcity of larger studies. When feasible, test performance was plotted for visual inspection and combined sensitivity and specificity were calculated.

Results. Eleven studies met criteria to evaluate test performance of PET to diagnose metastatic differentiated thyroid cancer. Across the studies sensitivity ranged from 62% to 100% and specificity ranged from 0% to 100%. The two studies that reported on at least 10 subjects each to provide estimates of both sensitivity and specificity reported sensitivity of 88% and 96% and specificity of 100% and 73%, respectively. Because of the variability of results among the studies, combined estimates of test performance across the 11 studies are not reliable. Six studies met criteria to evaluate test performance of PET to diagnose metastatic medullary thyroid cancer. All were small and no reliable estimate of PET test performance could be made. Six peer reviewed studies (and one letter) reported data on effect of PET on clinical management or outcomes of differentiated thyroid cancer. Among the studies, about 80% of subjects had treatment of metastatic disease after positive PET; about 20% had no change in clinical management. In most studies, it is unclear whether treatment decisions were influenced by PET results. About one-third of subjects had reported cure after positive PET and one-third had recurrence of cancer; no data were provided on the remaining subjects. Duration of follow-up was generally brief or not reported. Data reporting was generally incomplete, making proper analysis difficult. Two studies reported data on effect of PET on clinical management or outcomes of medullary thyroid cancer. Of 9 subjects, 3 had reported surgical cure. No data were reported on duration of follow-up. Insufficient data have been reported about PET for rarer forms of thyroid cancer to draw conclusions.

Conclusions. Only two studies were sufficiently powered to provide potentially reliable estimates of PET sensitivity and specificity for diagnosing metastatic disease in patients with treated differentiated thyroid cancer, elevated thyroglobulin, and negative WBS. Sensitivity was 88% and 96%; specificity was 100% and 73%, respectively. However, the poor quality and small size of these studies limit the reliability of the test performance estimates. Smaller studies reported wide ranges of sensitivity and specificity. Insufficient data exist to estimate the test performance of PET for treated medullary thyroid cancer or other rarer forms of thyroid cancer. Limited data suggest that PET may affect management of patients with differentiated cancer and may result in cure of at least one-third of such patients. However, study quality was too poor and follow-up duration was too short (or not reported) to allow a definitive conclusion. Insufficient data exist to estimate the effect of PET on treatment management of patients with medullary or other rarer forms of thyroid cancer. Overall study quality was poor and study sample sizes were small. Future well-designed, clearly reported studies that focus on patients with treated thyroid cancer, elevated biochemical markers of metastasis and negative standard imaging tests are needed to define test performance and effect on clinical management and outcome of PET.