# REFERENCES

1 James C, Starks M, MacGillivray DC, White J. The use of imaging studies in the diagnosis and management of thyroid cancer and hyperparathyroidism. Surgical Oncology Clinics of North America. 1999;8(1):145-169. [pmid: 9824366].
2 Price DC. Radioisotopic evaluation of the thyroid and the parathyroids. Radiologic Clinics of North America. 1993;31(5):991-1015. [pmid: 8362060].
3 Zettinig G, Leitha T, Niederle B, Kaserer K, Becherer A, Kletter K, et al. FDG positron emission tomographic, radioiodine, and MIBI imaging in a patient with poorly differentiated insular thyroid carcinoma. Clinical Nuclear Medicine. 2001;26(7):599-601. [pmid: 11416738].
4 Thyroid Carcinoma Task Force. AACE/AAES Medical/Surgical Guidelines for Clinical Practice: Management of Thyroid Carcinoma. Endocrine Practice. 2001;7(3):202-220. [pmid: 11430305].
5 Lowe VJ, Naunheim KS. Current role of positron emission tomography in thoracic oncology. Thorax. 1998;53(8):703-712. [pmid: 9828860].
6 Joensuu H, Ahonen A, Klemi PJ. 18F-fluorodeoxyglucose imaging in preoperative diagnosis of thyroid malignancy. European Journal of Nuclear Medicine. 1988;13(10):502-506. [pmid: 3371370].
7 Grunwald F, Kalicke T, Feine U, Lietzenmayer R, Scheidhauer K, Dietlein M, et al. Fluorine-18 fluorodeoxyglucose positron emission tomography in thyroid cancer: results of a multicentre study. European Journal of Nuclear Medicine. 1999;26(12):1547-1552. [pmid: 10638405].
8 Helal BO, Merlet P, Toubert ME, Franc B, Schvartz C, Gauthier-Koelesnikov H, et al. Clinical impact of (18)F-FDG PET in thyroid carcinoma patients with elevated thyroglobulin levels and negative (131)I scanning results after therapy. Journal of Nuclear Medicine. 2001;42(10):1464-1469. [pmid: 11585858].
9 Chung JK, So Y, Lee JS, Choi CW, Lim SM, Lee DS, et al. Value of FDG PET in papillary thyroid carcinoma with negative 131I whole-body scan. Journal of Nuclear Medicine. 1999;40(6):986-992. [pmid: 10452315].
10 Wang W, Macapinlac H, Larson SM, Yeh SD, Akhurst T, Finn RD, et al. [18F]-2-fluoro-2-deoxy-D-glucose positron emission tomography localizes residual thyroid cancer in patients with negative diagnostic (131)I whole body scans and elevated serum thyroglobulin levels. Journal of Clinical Endocrinology & Metabolism. 1999;84(7):2291-2302. [pmid: 10404792].
11 Wang W, Larson SM, Fazzari M, Tickoo SK, Kolbert K, Sgouros G, et al. Prognostic value of [18F]fluorodeoxyglucose positron emission tomographic scanning in patients with thyroid cancer. Journal of Clinical Endocrinology & Metabolism. 2000;85(3):1107-1113. [pmid: 10720047].
12 Brandt-Mainz K, Muller SP, Sonnenschein W, Bockisch A. Technetium-99m-furifosmin in the follow-up of differentiated thyroid carcinoma. Journal of Nuclear Medicine. 1998;39(9):1536-1541. [pmid: 9744338].
13 Grunwald F, Menzel C, Bender H, Palmedo H, Willkomm P, Ruhlmann J, et al. Comparison of 18FDG-PET with 131iodine and 99mTc-sestamibi scintigraphy in differentiated thyroid cancer. Thyroid. 1997;7(3):327-335. [pmid: 9226199].
14 Frilling A, Gorges R, Tecklenborg K, Gassmann P, Bockhorn M, Clausen M, et al. Value of preoperative diagnostic modalities in patients with recurrent thyroid carcinoma. Surgery. 2000;128(6):1067-1074. [pmid: 11114644].
15 Alnafisi NS, Driedger AA, Coates G, Moote DJ, Raphael SJ. FDG PET of recurrent or metastatic 131I-negative papillary thyroid carcinoma. Journal of Nuclear Medicine. 2000;41(6):1010-1015. [pmid: 10855626].
16 van Tol KM, Jager PL, Dullaart RP, Links TP. Follow-up in patients with differentiated thyroid carcinoma with positive 18F-fluoro-2-deoxy-D-glucose-positron emission tomography results, elevated thyroglobulin levels, and negative high-dose 131I posttreatment whole body scans. [letter]. Journal of Clinical Endocrinology & Metabolism. 2000;85(5):2082-2083. [pmid: 10843201].
17 Muros MA, Llamas-Elvira JM, Ramirez-Navarro A, Gomez MJ, Rodriguez-Fernandez A, Muros T, et al. Utility of fluorine-18-fluorodeoxyglucose positron emission tomography in differentiated thyroid carcinoma with negative radioiodine scans and elevated serum thyroglobulin levels. American Journal of Surgery. 2000;179(6):457-461. [pmid: 11004330].
18 Stokkel MP, de Klerk JH, Zelissen PM, Koppeschaar HP, van Rijk PP. Fluorine-18 fluorodeoxyglucose dual-head positron emission tomography in the detection of recurrent differentiated thyroid cancer: preliminary results. European Journal of Nuclear Medicine. 1999;26(12):1606-1609. [pmid: 10638413].
19 Conti PS, Durski JM, Bacqai F, Grafton ST, Singer PA. Imaging of locally recurrent and metastatic thyroid cancer with positron emission tomography. Thyroid. 1999;9(8):797-804. [pmid: 10482373].
20 Lind P, Kumnig G, Matschnig S, Heinisch M, Gallowitsch HJ, Mikosch P, et al. The role of F-18FDG PET in thyroid cancer. Acta Medica Austriaca. 2000;27(2):38-41. [pmid: 10812462].
21 Adams S, Baum R, Rink T, Schumm-Drager PM, Usadel KH, Hor G. Limited value of fluorine-18 fluorodeoxyglucose positron emission tomography for the imaging of neuroendocrine tumours. European Journal of Nuclear Medicine. 1998;25(1):79-83. [pmid: 9396878].
22 Adams S, Baum RP, Hertel A, Schumm-Drager PM, Usadel KH, Hor G. Metabolic (PET) and receptor (SPET) imaging of well- and less well-differentiated tumours: comparison with the expression of the Ki-67 antigen. Nuclear Medicine Communications. 1998;19(7):641-647. [pmid: 9853344].
23 Musholt TJ, Musholt PB, Dehdashti F, Moley JF. Evaluation of fluorodeoxyglucose-positron emission tomographic scanning and its association with glucose transporter expression in medullary thyroid carcinoma and pheochromocytoma: a clinical and molecular study. Surgery. 1997;122(6):1049-1060. [pmid: 9426419].
24 Gasparoni P, Rubello D, Ferlin G. Potential role of fluorine-18-deoxyglucose (FDG) positron emission tomography (PET) in the staging of primitive and recurrent medullary thyroid carcinoma. Journal of Endocrinological Investigation. 1997;20(9):527-530. [pmid: 9413806].
25 Simon GH, Nitzsche EU, Laubenberger JJ, Einert A, Moser E. PET imaging of recurrent medullary thyroid cancer. Nuklearmedizin. 1996;35(3):102-104. [pmid: 8710526].
26 Grunwald F, Menzel C, Bender H, Palmedo H, Otte R, Fimmers R, et al. Redifferentiation therapy-induced radioiodine uptake in thyroid cancer. Journal of Nuclear Medicine. 1998;39(11):1903-1906. [pmid: 9829580].
27 Fridrich L, Messa C, Landoni C, Lucignani G, Moncayo R, Kendler D, et al. Whole-body scintigraphy with 99Tcm-MIBI, 18F-FDG and 131I in patients with metastatic thyroid carcinoma. Nuclear Medicine Communications. 1997;18(1):3-9. [pmid: 9061694].
28 Jadvar H, McDougall IR, Segall GM. Evaluation of suspected recurrent papillary thyroid carcinoma with [18F]fluorodeoxyglucose positron emission tomography. Nuclear Medicine Communications. 1998;19(6):547-554. [pmid: 10234658].
29 Grunwald F, Schomburg A, Bender H, Klemm E, Menzel C, Bultmann T, et al. Fluorine-18 fluorodeoxyglucose positron emission tomography in the follow-up of differentiated thyroid cancer. European Journal of Nuclear Medicine. 1996;23(3):312-319. [pmid: 8599963].
30 Lips P, Comans EF, Hoekstra OS, van der Poest CE, van Mourik JC, Teule GJ. Positron emission tomography for the detection of metastases of differentiated thyroid carcinoma. Netherlands Journal of Medicine. 2000;57(4):150-156. [pmid: 11006491].
31 Huang TS, Chieng PU, Chang CC, Yen RF. Positron emission tomography for detecting iodine-131 nonvisualized metastasis of well-differentiated thyroid carcinoma: two case reports. Journal of Endocrinological Investigation. 1998;21(6):392-398. [pmid: 9699132].
32 Bakheet SM, Powe JE, Hammami MM, Ahmed M. Comparison of F-18 FDG to I-123 and I-131 scans in thyroid carcinoma. Clinical Nuclear Medicine. 1997;22(6):438-439. [pmid: 9193832].
33 Mechanick JI, Kim CK, Krynyckyi BR, Machac J, Urken ML. Multiple papillary thyroid carcinoma metastases revealed on position emission tomography scan in a patient with negative 131I scan. Thyroid. 2000;10(10):929-930. [pmid: 11081260].
34 Tiepolt C, Beuthien-Baumann B, Hliscs R, Bredow J, Kuhne A, Kropp J, et al. 18F-FDG for the staging of patients with differentiated thyroid cancer: comparison of a dual-head coincidence gamma camera with dedicated PET. Annals of Nuclear Medicine. 2000;14(5):339-345. [pmid: 11108162].
35 Schluter B, Bohuslavizki KH, Beyer W, Plotkin M, Buchert R, Clausen M. Impact of FDG PET on patients with differentiated thyroid cancer who present with elevated thyroglobulin and negative 131I scan. Journal of Nuclear Medicine. 2001;42(1):71-76. [pmid: 11197983].
36 Moog F, Linke R, Manthey N, Tiling R, Knesewitsch P, Tatsch K, et al. Influence of thyroid-stimulating hormone levels on uptake of FDG in recurrent and metastatic differentiated thyroid carcinoma. Journal of Nuclear Medicine. 2000;41(12):1989-1995. [pmid: 11138683].
37 Feine U, Lietzenmayer R, Hanke JP, Held J, Wohrle H, Muller-Schauenburg W. Fluorine-18-FDG and iodine-131-iodide uptake in thyroid cancer. Journal of Nuclear Medicine. 1996;37(9):1468-1472. [pmid: 8790195].
38 Dietlein M, Scheidhauer K, Voth E, Theissen P, Schicha H. Fluorine-18 fluorodeoxyglucose positron emission tomography and iodine-131 whole-body scintigraphy in the follow-up of differentiated thyroid cancer. European Journal of Nuclear Medicine. 1997;24(11):1342-1348. [pmid: 9371865].
39 Shiga T, Tsukamoto E, Nakada K, Morita K, Kato T, Mabuchi M, et al. Comparison of (18)F-FDG, (131)I-Na, and (201)Tl in diagnosis of recurrent or metastatic thyroid carcinoma. Journal of Nuclear Medicine. 2001;42(3):414-419. [pmid: 11337516].
40 Sasaki M, Ichiya Y, Kuwabara Y, Akashi Y, Yoshida T, Fukumura T, et al. An evaluation of FDG-PET in the detection and differentiation of thyroid tumours. Nuclear Medicine Communications. 1997;18(10):957-963. [pmid: 9392798].
41 Brandt-Mainz K, Muller SP, Gorges R, Saller B, Bockisch A. The value of fluorine-18 fluorodeoxyglucose PET in patients with medullary thyroid cancer. European Journal of Nuclear Medicine. 2000;27(5):490-496. [pmid: 10853802].
42 Lind P, Gallowitsch HJ, Mikosch P, Kresnik E, Gomez I, Kumnig G, et al. Comparison of different tracers in the follow up of differentiated thyroid carcinoma. Acta Medica Austriaca. 1999;26(4):115-117. [pmid: 10526627].
43 Dietlein M, Moka D, Scheidhauer K, Schmidt M, Theissen P, Voth E, et al. Follow-up of differentiated thyroid cancer: comparison of multiple diagnostic tests. Nuclear Medicine Communications. 2000;21(11):991-1000. [pmid: 11192718].
44 Dietlein M, Scheidhauer K, Voth E, Theissen P, Schicha H. Follow-up of differentiated thyroid cancer: what is the value of FDG and sestamibi in the diagnostic algorithm?. Nuklearmedizin. 1998;37(1):12-17. [pmid: 9467164].
45 Yeo JS, Chung JK, So Y, Kim S, Lee E, Lee DS, et al. F-18-fluorodeoxyglucose positron emission tomography as a presurgical evaluation modality for I-131 scan-negative thyroid carcinoma patients with local recurrence in cervical lymph nodes. Head & Neck. 2001;23(2):94-103. [pmid: 11303639].
46 Altenvoerde G, Lerch H, Kuwert T, Matheja P, Schafers M, Schober O. Positron emission tomography with F-18-deoxyglucose in patients with differentiated thyroid carcinoma, elevated thyroglobulin levels, and negative iodine scans. Langenbecks Archives of Surgery. 1998;383(2):160-163.