# REFERENCES

Aaberge L, Nordstrand K, Dragsund M, et al. Transmyocardial revascularization with CO2 laser in patients with refractory angina pectoris. Clinical results from the Norwegian randomized trial. Journal of the American College of Cardiology. 2000;35(5):1170-1177. [pmid: 10758957].
Aaberge L, Rootwelt K, Blomhoff S, et al. Continued symptomatic improvement three to five years after transmyocardial revascularization with CO(2) laser: a late clinical follow-up of the Norwegian Randomized trial with transmyocardial revascularization. Journal of the American College of Cardiology. 2002;39(10):1588-1593. [pmid: 12020484].
Agarwal R, Ajit M, Kurian VM, et al. Transmyocardial laser revascularization: early results and 1-year follow-up.[see comment]. Annals of Thoracic Surgery. 1999;67(2):432-436. [pmid: 10197665].
Allen KB, Dowling RD, Angell WW. Transmyocardial Revascularization: 5-Year Flow-Up of a Prospective, Randomized Multicenter Trial. Annals of Thoracic Surgery. 2004;77:1228-1234. [pmid: 15063241].
Allen KB, Dowling RD, DelRossi AJ, et al. Transmyocardial laser revascularization combined with coronary artery bypass grafting: a multicenter, blinded, prospective, randomized, controlled trial.[see comment]. Journal of Thoracic & Cardiovascular Surgery. 2000;119(3):540-549. [pmid: 10694615].
Allen KB, Dowling RD, Fudge TL, et al. Comparison of transmyocardial revascularization with medical therapy in patients with refractory angina.[see comment]. New England Journal of Medicine. 1999;341(14):1029-1036. [pmid: 10502592].
Allen KB, Dowling RD, Heimansohn DA, et al. Transmyocardial revascularization utilizing a holmium:YAG laser. European Journal of Cardio-Thoracic Surgery. 1998;(14 Suppl 1):S100-S104. [pmid: 9814802].
Burkhoff D, Schmidt S, Schulman SP, et al. Transmyocardial laser revascularisation compared with continued medical therapy for treatment of refractory angina pectoris: a prospective randomised trial. ATLANTIC Investigators. Angina Treatments-Lasers and Normal Therapies in Comparison.[comment]. Lancet. 1999;354(9182):885-890. [pmid: 10489946].
Burkhoff D, Wesley MN, Resar JR, et al. Factors correlating with risk of mortality after transmyocardial revascularization. Journal of the American College of Cardiology. 1999;34(1):55-61. [pmid: 10399992].
Burns SM, Sharples LD, Tait S, et al. The transmyocardial laser revascularization international registry report. European Heart Journal. 1999;20(1):31-37. [pmid: 10075139].
Cooley DA, Frazier OH, Kadipasaoglu KA, et al. Transmyocardial laser revascularization: clinical experience with twelve-month follow-up. Journal of Thoracic & Cardiovascular Surgery. 1996;111(4):791-797. discussion 797-9. [pmid: 8614139].
De Carlo M, Milano AD, Pratali S, et al. Symptomatic improvement after transmyocardial laser revascularization: how long does it last?. Annals of Thoracic Surgery. 2000;70(3):1130-1133. [pmid: 11016395].
DIRECT Investigators. DMR in Regeneration of Endomyocardial Channels Trial (DIRECT). ACC Clinical Trials - March 2001. Available online: http://www.acc.org/education/online/trials/acc2001/direct.htm.
Dowling RD, Petracek MR, Selinger SL, et al. Transmyocardial revascularization in patients with refractory, unstable angina. Circulation. 1998;98(19 Suppl):II73-II75. discussion II75-6. [pmid: 9852884].
Frazier OH, March RJ, Horvath KA. Transmyocardial revascularization with a carbon dioxide laser in patients with end-stage coronary artery disease.[see comment]. New England Journal of Medicine. 1999;341(14):1021-1028. [pmid: 10502591].
Gray TJ, Burns SM, Clarke SC, et al. Percutaneous myocardial laser revascularization in patients with refractory angina pectoris. American Journal of Cardiology. 2003;91(6):661-666. [pmid: 12633794].
Gregoric I, Messner G, Couto WJ, et al. Off-pump coronary artery bypass grafting and transmyocardial laser revascularization via a left thoracotomy. Texas Heart Institute Journal. 2003;30(1):13-18. [pmid: 12638665].
Guleserian KJ, Maniar HS, Camillo CJ, et al. Quality of life and survival after transmyocardial laser revascularization with the holmium:YAG laser. Annals of Thoracic Surgery. 2003;75(6):1842-1847. discussion 1847-8. [pmid: 12822626].
Hattler BG, Griffith BP, Zenati MA, et al. Transmyocardial laser revascularization in the patient with unmanageable unstable angina. Annals of Thoracic Surgery. 1999;68(4):1203-1209. [pmid: 10543480].
Horvath KA, Aranki SF, Cohn LH, et al. Sustained angina relief 5 years after transmyocardial laser revascularization with a CO(2) laser. Circulation. 2001;104(12 Suppl 1):I81-I84. [pmid: 11568035].
Horvath KA, Cohn LH, Cooley DA, et al. Transmyocardial laser revascularization: results of a multicenter trial with transmyocardial laser revascularization used as sole therapy for end-stage coronary artery disease. Journal of Thoracic & Cardiovascular Surgery. 1997;113(4):645-653. discussion 653-4. [pmid: 9104973].
Huikeshoven M, van der Sloot JA, Tukkie R, et al. Improved quality of life after XeCl excimer transmyocardial laser revascularization: results of a randomized trial. Lasers in Surgery & Medicine. 2003;33(1):1-7. [pmid: 12866115].
Jones JW, Schmidt SE, Richman BW, et al. Holmium:YAG laser transmyocardial revascularization relieves angina and improves functional status. Annals of Thoracic Surgery. 1999;67(6):1596-1601. discussion 1601-2. [pmid: 10391261].
Kaul U, Shawl F, Singh B, et al. Percutaneous transluminal myocardial revascularization with a holmium laser system: procedural results and early clinical outcome.[see comment]. Catheterization & Cardiovascular Interventions. 1999;47(3):287-291. [pmid: 10402278].
Kornowski R, Baim DS, Moses JW, et al. Short- and intermediate-term clinical outcomes from direct myocardial laser revascularization guided by biosense left ventricular electromechanical mapping. Circulation. 2000;102(10):1120-1125. [pmid: 10973840].
Landolfo CK, Landolfo KP, Hughes GC, et al. Intermediate-term clinical outcome following transmyocardial laser revascularization in patients with refractory angina pectoris. Circulation. 1999;100(19 Suppl):II128-II133. [pmid: 10567291].
Lee LY, O'Hara MF, Finnin EB, et al. Transmyocardial laser revascularization with excimer laser: clinical results at 1 year. Annals of Thoracic Surgery. 2000;70(2):498-503. [pmid: 10969670].
Muxi A, Magrina J, Martin F, et al. Technetium 99m-labeled tetrofosmin and iodine 123-labeled metaiodobenzylguanidine scintigraphy in the assessment of transmyocardial laser revascularization. Journal of Thoracic & Cardiovascular Surgery. 2003;125(6):1493-1498. [pmid: 12830071].
Nagele H, Stubbe HM, Nienaber C, et al. Results of transmyocardial laser revascularization in non-revascularizable coronary artery disease after 3 years follow-up [ssee comments][see comment]. European Heart Journal. 1998;19(10):1525-1530. [pmid: 9820991].
Oesterle SN, Sanborn TA, Ali N, et al. Percutaneous transmyocardial laser revascularisation for severe angina: the PACIFIC randomised trial. Potential Class Improvement From Intramyocardial Channels.[comment]. Lancet. 2000;356(9243):1705-1710. [pmid: 11095257].
Peterson ED, Kaul P, Kaczmarek RG, et al. From controlled trials to clinical practice: monitoring transmyocardial revascularization use and outcomes. Journal of the American College of Cardiology. 2003;42(9):1611-1616. [pmid: 14607448].
Salem M, Rotevatn S, Stavnes S, et al. Usefullness and Safety of Percutaneous Myocardial Laser Revascularization for Refractory Angina Pectoris. The American Journal of Cardiology. 2004;93:1086-1091. [pmid: 15110197].
Schneider J, Diegeler A, Krakor R, et al. Transmyocardial laser revascularization with the holmium:YAG laser: loss of symptomatic improvement after 2 years. European Journal of Cardio-Thoracic Surgery. 2001;19(2):164-169. [pmid: 11167106].
Schofield PM, Sharples LD, Caine N, et al. Transmyocardial laser revascularisation in patients with refractory angina: a randomised controlled trial.[comment][erratum appears in Lancet 1999 May 15;353(9165):1714]. Lancet. 1999;353(9152):519-524. [pmid: 10028979].
Stamou SC, Boyce SW, Cooke RH, et al. One-year outcome after combined coronary artery bypass grafting and transmyocardial laser revascularization for refractory angina pectoris. American Journal of Cardiology. 2002;89(12):1365-1368. [pmid: 12062729].
Stone GW, Teirstein PS, Rubenstein R, et al. A prospective, multicenter, randomized trial of percutaneous transmyocardial laser revascularization in patients with nonrecanalizable chronic total occlusions.[see comment]. Journal of the American College of Cardiology. 2002;39(10):1581-1587. [pmid: 12020483].
Wehberg KE, Julian JS, Todd JC 3rd, et al. Improved patient outcomes when transmyocardial revascularization is used as adjunctive revascularization. Heart Surgery Forum. 2003;6(5):328-330. [pmid: 14721803].
Whitlow PL, DeMaio SJ Jr, Perin EC, et al. One-year results of percutaneous myocardial revascularization for refractory angina pectoris. American Journal of Cardiology. 2003;91(11):1342-1346. [pmid: 12767430].