# BIBLIOGRAPHY

Aaberge L, Nordstrand K, Dragsund M, et al. Transmyocardial revascularization with CO2 laser in patients with refractory angina pectoris. Clinical results from the Norwegian randomized trial. Journal of the American College of Cardiology. 2000;35(5):1170-1177. [pmid: 10758957].
Aaberge L, Rootwelt K, Blomhoff S, et al. Continued symptomatic improvement three to five years after transmyocardial revascularization with CO(2) laser: a late clinical follow-up of the Norwegian Randomized trial with transmyocardial revascularization. Journal of the American College of Cardiology. 2002;39(10):1588-1593. [pmid: 12020484].
Abo-Auda W, Benza RL. Transmyocardial and percutaneous myocardial revascularization: current concepts and future directions. Journal of Heart & Lung Transplantation. 2003;22(8):837-842. [pmid: 12909461].
Agarwal R, Ajit M, Kurian VM, et al. Transmyocardial laser revascularization: early results and 1-year follow-up.[see comment]. Annals of Thoracic Surgery. 1999;67(2):432-436. [pmid: 10197665].
Allen KB, Dowling RD, Angell WW. Transmyocardial Revascularization: 5-Year Flow-Up of a Prospective, Randomized Multicenter Trial. Annals of Thoracic Surgery. 2004;77:1228-1234. [pmid: 15063241].
Allen KB, Dowling RD, DelRossi AJ, et al. Transmyocardial laser revascularization combined with coronary artery bypass grafting: a multicenter, blinded, prospective, randomized, controlled trial.[see comment]. Journal of Thoracic & Cardiovascular Surgery. 2000;119(3):540-549. [pmid: 10694615].
Allen KB, Dowling RD, Fudge TL, et al. Comparison of transmyocardial revascularization with medical therapy in patients with refractory angina.[see comment]. New England Journal of Medicine. 1999;341(14):1029-1036. [pmid: 10502592].
Allen KB, Dowling RD, Heimansohn DA, et al. Transmyocardial revascularization utilizing a holmium:YAG laser. European Journal of Cardio-Thoracic Surgery. Suppl 1. 1998;14:S100-S104. [pmid: 9814802].
Al-Sheikh T, Allen KB, Straka SP, et al. Cardiac sympathetic denervation after transmyocardial laser revascularization. Circulation. 1999;100(2):135-140. [pmid: 10402442].
Arora RC, Hirsch GM, Hirsch K, Armour JA. Transmyocardial laser revascularization remodels the intrinsic cardiac nervous system in a chronic setting. Circulation. suppl I. 2001;104:I115-I120. [pmid: 11568041].
Bridges CR, Horvath KA, Nugent WC. The Society of Thoracic Surgeons Practice Guideline Series: Transmyocardial Laser Revascularization. Annals of Thoracic Surgery. 2004;77:1494-1502. [pmid: 15063304].
Burkhoff D, Schmidt S, Schulman SP, et al. Transmyocardial laser revascularisation compared with continued medical therapy for treatment of refractory angina pectoris: a prospective randomised trial. ATLANTIC Investigators. Angina Treatments-Lasers and Normal Therapies in Comparison.[comment]. Lancet. 1999;354(9182):885-890. (a). [pmid: 10489946].
Burkhoff D, Wesley MN, Resar JR, et al. Factors correlating with risk of mortality after transmyocardial revascularization. Journal of the American College of Cardiology. 1999;34(1):55-61. (b). [pmid: 10399992].
Burns SM, Sharples LD, Tait S, et al. The transmyocardial laser revascularization international registry report. European Heart Journal. 1999;20(1):31-37. [pmid: 10075139].
CardioGenesis Corporation. CardioGenesis Announces Status of PMR Submission. News release dated March 25, 2004. Access: www.cardiogenesis.com.
Chu VF, Giaid A, Kuang JQ, et al. Thoracic Surgery Directors Association Award. Angiogenesis in transmyocardial revascularization: comparison of laser versus mechanical punctures. Annals of Thoracic Surgery. 1999;68(2):301-307. discussion 307-8. [pmid: 10475386].
CMS (Centers for Medicare and Medicaid Services). Coverage Issues Manual. Centers for Medicare and Medicaid Services Website: Last updated November 26, 2003. Accessed June 22, 2004. Access: http://www.cms.hhs.gov/manuals/06_cim/ci00.asp.
Cooley DA, Frazier OH, Kadipasaoglu KA, et al. Transmyocardial laser revascularization: clinical experience with twelve-month follow-up. Journal of Thoracic & Cardiovascular Surgery. 1996;111(4):791-797. discussion 797-9. [pmid: 8614139].
De Carlo M, Milano AD, Pratali S, et al. Symptomatic improvement after transmyocardial laser revascularization: how long does it last?. Annals of Thoracic Surgery. 2000;70(3):1130-1133. [pmid: 11016395].
DIRECT Investigators. DMR in Regeneration of Endomyocardial Channels Trial (DIRECT). ACC Clinical Trials - March 2001. Available online: http://www.acc.org/education/online/trials/acc2001/direct.htm.
Dowling RD, Petracek MR, Selinger SL, et al. Transmyocardial revascularization in patients with refractory, unstable angina. Circulation. 1998;98(19 Suppl):II73-II75. discussion II75-6. [pmid: 9852884].
Fisher PE, Khomoto T, DeRosa CM, et al. Histologic analysis of transmyocardial channels: comparison of CO2 and holmium:YAG lasers. Annals of Thoracic Surgery. 1997;64(2):466-472. [pmid: 9262595].
Food and Drug Administration (FDA). Summary of Safety and Effectiveness – Eclipse TMR Holmium Laser System P970029. Food and Drug Administration Website 1999. Access: http://www.fda.gov/cdrh/pdf/P970029b.pdf.
Frazier OH, March RJ, Horvath KA. Transmyocardial revascularization with a carbon dioxide laser in patients with end-stage coronary artery disease.[see comment]. New England Journal of Medicine. 1999;341(14):1021-1028. [pmid: 10502591].
Gray TJ, Burns SM, Clarke SC, et al. Percutaneous myocardial laser revascularization in patients with refractory angina pectoris. American Journal of Cardiology. 2003;91(6):661-666. [pmid: 12633794].
Gregoric I, Messner G, Couto WJ, et al. Off-pump coronary artery bypass grafting and transmyocardial laser revascularization via a left thoracotomy. Texas Heart Institute Journal. 2003;30(1):13-18. [pmid: 12638665].
Guleserian KJ, Maniar HS, Camillo CJ, et al. Quality of life and survival after transmyocardial laser revascularization with the holmium:YAG laser. Annals of Thoracic Surgery. 2003;75(6):1842-1847. discussion 1847-8. [pmid: 12822626].
Hardy RI, Bove KE, James FW, et al. A histologic study of laser-induced transmyocardial channels. Lasers in Surgery and Medicine. 1987;6(6):563-573. [pmid: 3573931].
Hirsch GM, Thompson GW, Arora RC, Hirsch KJ, Sullivan JA, Armour JA. Transmrocardial laser revascularization does not denervate the canine heart. Annals of Thoracic Surgery. 1999;68:460-468. [pmid: 10475413].
Horvath KA, Chiu E, Maun DC, et al. Up-regulation of vascular endothelial growth factor mRNA and angiogenesis after transmyocardial laser revascularization. Annals of Thoracic Surgery. 1999;68(3):825-829. [pmid: 10509969].
Horvath KA, Cohn LH, Cooley DA, et al. Transmyocardial laser revascularization: results of a multicenter trial with transmyocardial laser revascularization used as sole therapy for end-stage coronary artery disease. Journal of Thoracic & Cardiovascular Surgery. 1997;113(4):645-653. discussion 653-4. [pmid: 9104973].
Hughes GC, Baklanov DV, Annex BH, et al. Denervation is not the long-term mechanism of action of transmyocardial laser revascularization. Circulation. 1999;100:1292.
Hughes GC, Kypson AP, Annex BH, et al. Induction of angiogenesis after TMR: a comparison of holmium:YAG, CO2, and excimer lasers. Annals of Thoracic Surgery. 2000;70:540-549.
Hughes GC, Baklanov DV, Biswas SS, et al. Regional cardiac sympathetic innervation early and late after transmyocardial laser revascularization. Journal of Cardiac Surgery. 2004;19:21-27. [pmid: 15108785].
Huikeshoven M, van der Sloot JA, Tukkie R, et al. Improved quality of life after XeCl excimer transmyocardial laser revascularization: results of a randomized trial. Lasers in Surgery & Medicine. 2003;33(1):1-7. [pmid: 12866115].
Huikeshoven M, Beek JF, van der Sloot JA, et al. 35 years of experimental research in transmyocardial revascularization: what have we learned?. Annals of Thoracic Surgery. Sep. 2002;74(3):956-970. [pmid: 12238883].
Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Controlled Clinical Trials. 1996;17(1):1-12. [pmid: 8721797].
Jones JW, Schmidt SE, Richman BW, et al. Holmium:YAG laser transmyocardial revascularization relieves angina and improves functional status. Annals of Thoracic Surgery. 1999;67(6):1596-1601. discussion 1601-2. [pmid: 10391261].
Kaul U, Shawl F, Singh B, et al. Percutaneous transluminal myocardial revascularization with a holmium laser system: procedural results and early clinical outcome.[see comment]. Catheterization & Cardiovascular Interventions. 1999;47(3):287-291. [pmid: 10402278].
Kornowski R, Baim DS, Moses JW, et al. Short- and intermediate-term clinical outcomes from direct myocardial laser revascularization guided by biosense left ventricular electromechanical mapping. Circulation. 2000;102(10):1120-1125. [pmid: 10973840].
Kwong KF, Kanellopoulos GK, Nickols JC, et al. Transmyocardial laser treatment denervates canine myocardium. Journal of Thoracic Cardiovascular Surgery. 1997;114(6):883-889. discussion 889-90. [pmid: 9434682].
Landolfo CK, Landolfo KP, Hughes GC, et al. Intermediate-term clinical outcome following transmyocardial laser revascularization in patients with refractory angina pectoris. Circulation. 1999;100(19 Suppl):II128-II133. [pmid: 10567291].
Le E, Powers ER, Leong-Poi H, Rim SJ, Pelberg RA, Kaul S. Transmyocardial revascularization ameliorates ischemia by cardiac denervation and not by angiogenesis: new insights using contrast echocardiography. Circulation. 2000;102:3188.
Lee LY, O'Hara MF, Finnin EB, et al. Transmyocardial laser revascularization with excimer laser: clinical results at 1 year. Annals of Thoracic Surgery. 2000;70(2):498-503. [pmid: 10969670].
Martin JS, Sayeed-Shah U, Byrne JG, et al. Excimer versus carbon dioxide transmyocardial laser revascularization: effects on regional left ventricular function and perfusion. Annals of Thoracic Surgery. 2000;69:1811-1816. [pmid: 10892928].
Mirhoseini M, Cayton MM. Revascularization of the heart by laser. Journal of Microsurgery. Jun. 1981;2(4):253-260. [pmid: 7310316].
Muhkerjee D, Comella K, Bhatt D, et al. Direct Myocardial Revascularization and Angiogenesis-How Many Patients Might Be Eligible?. American Journal of Cardiology. 1999;84(5):598-600. [pmid: 10482164].
Muxi A, Magrina J, Martin F, et al. Technetium 99m-labeled tetrofosmin and iodine 123-labeled metaiodobenzylguanidine scintigraphy in the assessment of transmyocardial laser revascularization. Journal of Thoracic & Cardiovascular Surgery. 2003;125(6):1493-1498. [pmid: 12830071].
Myers J, Oesterle SN, Jones J, Burkhoff D. Do transmyocardial and percutaneous laser revascularization induce silent ischemia? An assessment by exercise testing. American Heart Journal. 2002;143:1052-1057. [pmid: 12075263].
Nagele H, Stubbe HM, Nienaber C, et al. Results of transmyocardial laser revascularization in non-revascularizable coronary artery disease after 3 years follow-up [ssee comments][see comment]. European Heart Journal. 1998;19(10):1525-1530. [pmid: 9820991].
Oesterle SN, Sanborn TA, Ali N, et al. Percutaneous transmyocardial laser revascularisation for severe angina: the PACIFIC randomised trial. Potential Class Improvement From Intramyocardial Channels.[comment]. Lancet. 2000;356(9243):1705-1710. [pmid: 11095257].
Peterson ED, Kaul P, Kaczmarek RG, et al. From controlled trials to clinical practice: monitoring transmyocardial revascularization use and outcomes. Journal of the American College of Cardiology. 2003;42(9):1611-1616. [pmid: 14607448].
Pifarre R, Jasuja ML, Lynch RD, Neville WE. Myocardial revascularization by transmyocardial acupuncture. A physiologic impossibility. Journal of Thoracic Cardiovascular Surgery. 1969;58(3):424-431. [pmid: 5811026].
Sackett DL, Straus SE, Richardson WS, et al. Prognosis. Evidence-Based Medicine: How to Practice and Teach EBM (Second Edition). Edinburgh. Churchill Livingston/Harcourt Publishers Limited. 2000.
Salem M, Rotevatn S, Stavnes S, et al. Usefullness and Safety of Percutaneous Myocardial Laser Revascularization for Refractory Angina Pectoris. The American Journal of Cardiology. 2004;93:1086-1091. [pmid: 15110197].
Saririan M, Eisenberg MJ. Myocardial laser revascularization for the treatment of end-stage coronary artery disease. Journal of the American College of Cardiology. 2003;41(2):173-183. [pmid: 12535804].
Schneider J, Diegeler A, Krakor R, et al. Transmyocardial laser revascularization with the holmium:YAG laser: loss of symptomatic improvement after 2 years. European Journal of Cardio-Thoracic Surgery. 2001;19(2):164-169. [pmid: 11167106].
Schofield PM, Sharples LD, Caine N, et al. Transmyocardial laser revascularisation in patients with refractory angina: a randomised controlled trial.[comment][erratum appears in Lancet 1999 May 15;353(9165):1714]. Lancet. 1999;353(9152):519-524. [pmid: 10028979].
Sen PK, Udwadia TE, Kinare SG, Parulkar GB. Transmyocardial Acupuncture: A new approach to myocardial revascularization. Journal of Thoracic Cardiovascular Surgery. 1965;50:181-189. [pmid: 14321516].
Stamou SC, Boyce SW, Cooke RH, et al. One-year outcome after combined coronary artery bypass grafting and transmyocardial laser revascularization for refractory angina pectoris. American Journal of Cardiology. 2002;89(12):1365-1368. [pmid: 12062729].
Stone GW, Teirstein PS, Rubenstein R, et al. A prospective, multicenter, randomized trial of percutaneous transmyocardial laser revascularization in patients with nonrecanalizable chronic total occlusions.[see comment]. Journal of the American College of Cardiology. 2002;39(10):1581-1587. [pmid: 12020483].
Whittaker P. Transmyocardial revascularization: the fate of myocardial channels. Annals of Thoracic Surgery. 1999;68(6):2376-2382. [pmid: 10617048].
Whitlow PL, DeMaio SJ Jr, Perin EC, et al. One-year results of percutaneous myocardial revascularization for refractory angina pectoris. American Journal of Cardiology. 2003;91(11):1342-1346. [pmid: 12767430].
Yamamoto N, Kohmoto T, Gu A, et al. Angiogenesis is enhanced in ischemic canine myocardium by transmyocardial laser revascularization. Journal of the American College of Cardiology. 1998;31:1426-1433. [pmid: 9581745].