# RESULTS

Of the 75 full-text papers reviewed, 38 (51 percent) met the inclusion criteria. Of these, 14 (37 percent) were RCTs and 21 (55 percent) were longitudinal observational studies (Table 1). Three observational studies included patients receiving TMR as sole therapy and TMR plus CABG. Three studies (eight percent) providing additional long-term follow-up information for included RCT papers are mentioned briefly with their primary paper summaries and have separate evidence tables in Appendix 8.4.

All studies together contributed a total of 3602 TMR procedures conducted alone, 3031 TMR procedures done with CABG, and 955 PMR procedures.

## 4.1 Efficacy – Randomized Clinical Trials

### 4.1.1 TMR

#### 4.1.1.1 Overview

Seven trials of TMR versus medical therapy met the inclusion criteria. Two of those trials also have published extended follow-up data and these are included here as well.

Quality scores for the included studies were 2 or 3 (on a 4-point scale). No TMR study was double-blinded. Three were multicenter trials, and five included more than 100 patients. Mean age of the patients was between 60 and 64 years. Prior myocardial infarction was present in 64 percent to 80 percent of patients.

None of the TMR-versus-medical therapy trials indicated a benefit in terms of mortality at 1 year. The only benefit in significant survival following TMR as sole therapy compared to medical treatment was found in a 5-year follow up of one of the included trials. All trials showed statistically significant improvements in angina symptoms at 1 year and when assessed longer term. One trial demonstrated improved myocardial perfusion in some patients [Frazier 1999]. Two trials observed reductions in hospitalizations or of coronary events at 1 year [Allen, 1999; Frazier, 1999], and two indicated improved exercise time [Allen, 1999; Burkhoff, 1999]; others did not find those benefits. Four trials that evaluated quality of life (using the Duke Activity Status Index [DASI] or Seattle Angina Questionnaire [SAQ]) found significant improvements at 1 year [Allen, 1999; Frazier, 1999; Burkhoff, 1999; Schofield, 1999].

#### 4.1.1.2 Summaries

Aaberge and colleagues [Aaberge, 2000] reported the results of a single-center Norwegian trial in which 100 patients with refractory angina not amenable to traditional revascularization were randomized to receive TMR or medical therapy. A CO_2_ laser was used. Of the patients randomized to TMR, 76 percent were in New York Heart Association (NYHA) class III, and 24 percent were in NYHA class IV. These authors found no improvement in 30-day or 12-month mortality. Thirty-day mortality was four percent in the TMR group and zero percent in the control group. Twelve-month mortality was 12 percent and eight percent, respectively. At 1 year, 39 percent of the TMR patients experienced an improvement of two or more NYHA functional classes compared with zero percent of the medically treated group. With regard to other outcomes, there was no evident difference between TMR and medically treated patients in total exercise time or maximal oxygen consumption. However, time to chest pain was significantly longer in TMR versus medically managed patients, and angina was reported as an exercise-limiting factor in significantly fewer TMR than medically managed patients (62 percent vs. 76 percent).

In a follow up of the same group of patients, Aaberge and associates reported 32-month to 60-month outcomes (mean 43 months) [Aaberge, 2002]. Again, no benefit was noted in mortality, which was 24 percent in the medical therapy group and 22 percent in the TMR. However, 60 percent of the TMR patients were in NYHA class I or II, whereas 16 percent of the medically treated patients were in class II or III (none were in class I). Twenty-four percent of patients in the TMR group improved by two or more NYHA functional classes compared with three percent of the medically treated patients.

Allen and coworkers [Allen, 1999] reported a 275 patient RCT in which Ho:YAG laser TMR was compared with medical therapy. All patients were reported to have medically refractory CCS class IV angina. Under an FDA-approved protocol, a priori criteria were prospectively defined to permit crossover of medically managed patients, allowing unstable patients to receive TMR. Thirty-day mortality was similar in both groups: five percent in the TMR group and two percent in the control group. One-year Kaplan-Meier survival was similar between TMR (84 percent) and medically managed (89 percent) patients. After 12 months of follow up, 76 percent of the patients in the TMR group and 32 percent of the patients treated medically had a reduction in angina of two or more CCS classes. Angina improvement in crossover patients was similar to that observed for patients randomized to TMR. Cardiac-related re-hospitalization was less common in the TMR group (33 percent) than in the medically treated group (61 percent). Patients randomized to TMR also had a significantly greater exercise tolerance (5.0 vs. 3.9 metabolic equivalents). A significant improvement was also noted in quality-of-life scores and rates of cardiac-related re-hospitalization.

Recently, a 5-year follow up of this work has been reported [Allen, 2004]. Long-term survival was significantly increased in patients randomized to TMR versus patients randomized to medical therapy (65 percent vs. 52 percent) and was found to be significantly predicted by 1-year angina improvement in TMR patients. Reductions in angina of two or more classes were found in 88 percent of the TMR group, compared to only 44 percent of the medical treated patients.

Burkhoff and associates [Burkhoff, 1999a] performed a prospective, multicenter, RCT of Ho:YAG laser TMR compared with medical therapy. One hundred eighty-two patients from 16 centers in the United States were randomly assigned to undergo TMR (n = 92) or medical management (n = 90). All subjects had CCS class III or IV angina (38 percent class III, 62 percent class IV). Operative mortality rate was low (one percent), while 12-month mortality was similar for TMR (five percent) and medically treated patients (10 percent). At 12 months, 52 percent of TMR and 86 percent of medically treated patients had CCS class III or IV angina. In addition, TMR was associated with statistically significant greater exercise tolerance and better quality of life as compared with medical therapy.

Frazier and colleagues published the results of an RCT conducted in 12 US Centers. Patients where randomized to CO_2_ laser TMR or medical therapy and followed for 12 months [Frazier, 1999]. Sixty-nine percent of the patients assigned to TMR and 63 percent of the patients assigned to medical therapy had CCS class IV angina. Sixty (60 percent) of the medically treated patients who developed unstable angina crossed over to TMR therapy. Angina reduced two or more CCS classes for 72 percent of the patients in the TMR group and 13 percent of patients receiving the medical therapy. Although total survival was not different in the treatment arms at 30 days (three percent vs. seven percent) or 12 months (15 percent vs. 21 percent), event-free survival was higher in TMR patients compared to medically managed patients at 1 year (66 percent vs. 11 percent). Survival free of cardiac events was defined as freedom from death, Q-wave myocardial infarction, cardiac-related hospitalization, and subsequent revascularization. The percentage of myocardial segments with fixed or reversible perfusion defects was assessed at 12 months using thallium 201 single-photon emission computed tomographic (SPECT) imaging. This percentage decreased by an average of 20 percent in the TMR group and worsened by 27 percent in the medical treatment group. Patients in the TMR group had a greater improvement (38 percent) in their quality of life than patients in the medical treatment arm (six percent). Admissions for unstable angina were two percent in the TMR group and 40 percent in the medical group. Angina was improved by two or more classes in 72 percent of the patients receiving TMR and in 13 percent of those receiving medical therapy.

Huikeshoven and colleagues have reported the results of a Dutch single-center trial. Thirty patients were randomly assigned to receive XeCl TMR or medical therapy [Huikeshoven, 2003]. No differences in survival were identified. No deaths were reported for the medically managed patients in the 12-month follow up, while TMR patients had a seven percent 12-month mortality. Quality-of-life scores (EuroQol, SF-24, SAQ) were significantly better in the TMR group than in the control group.

Jones and colleagues [Jones, 1999] performed an RCT in a single US center. In this trial, 86 patients were assigned to receive either Ho:YAG TMR or medical therapy. All had advanced cardiac ischemia with CCS class III or IV angina, took at least two cardiac medications at maximum doses, and were ineligible for angioplasty or bypass. Twelve-month survivals were the same (12 percent) for both groups. At 1 year TMR patients had lower mean angina class than control patients (1.71 ± 0.2 vs. 3.86 ± 0.05). Exercise tolerance time at 1 year was better in TMR patients than control group patients (490 ± 17 seconds vs. 294 ± 12 seconds).

Schofield and colleagues [Schofield, 1999] reported a single-center, prospective, randomized trial in which 188 patients were randomly assigned to CO_2_ laser TMR or medical therapy. Mortality at 30 days was zero percent in the control group and five percent in the TMR group, while at 12 months it was 11 percent in the TMR group and four percent in the medically treated group, although the differences in mortality were not statistically significant. The authors reported significantly less severe angina symptoms in the TMR group. Twenty-five percent of the TMR group but only four percent of the medical group had a reduction of two or more CCS classes. At 1 year, investigators identified a doubling of the fixed defects in the medically managed group and no increase in fixed defects in the TMR group. There were, however, no significant differences in exercise capacity.

### 4.1.2 TMR with CABG

#### 4.1.2.1 Overview

Only one study was identified in this category. This multicenter trial had a quality score of 3 (of a possible 4). This trial has extended follow-up data after the first publication, which is in press for publication in August 2004.

#### 4.1.2.2 Summaries

Allen and colleagues [Allen, 2000] reported a US multicenter trial in which 263 patients whose standard of care was CABG and who had one or more ischemic areas not amenable to bypass grafting were prospectively randomized to receive CABG plus TMR to areas not graftable (n = 132) or CABG with non-graftable areas left unrevascularized (n = 131). Mean age of these patients was 64 years; 34 percent had previous myocardial infarction, and mean EF was 51 percent. The operative mortality rate after CABG plus TMR was 1.5 percent versus 7.6 percent after CABG alone, although the Parsonnet-predicted mortality risk was comparable (6.3 percent, CABG plus TMR vs. 6.6 percent, CABG alone). One-year survival (95 percent vs. 89 percent) and freedom from major adverse cardiac events defined as death or myocardial infarction (92 percent vs. 86 percent) favored the combination of CABG plus TMR. Baseline to 12-month improvement in angina and exercise treadmill scores was similar between groups.

A follow-up study of the above trial assessed the long-term results of 218 of the original 263 patients (83 percent) [Allen, in press]. Kaplan-Meier survival up to 6 years was similar between CABG/TMR and CABG alone patients (76 percent vs. 80 percent). Using an intention-to-treat analysis based on independent blinded assessments, the 5-year follow up indicated that both groups experienced significant angina improvement from baseline; however, compared with patients receiving CABG alone, the TMR-plus-CABG group had a statistically lower mean angina score (0.4 ± 0.7 vs. 0.7 ± 1.1), a statistically lower proportion of patients with class III or IV angina (0 percent [0/68] vs. 10 percent [6/60]), and a trend towards greater number of angina-free patients (78 percent [53/68] vs. 63 percent [38/60]).

### 4.1.3 PMR

#### 4.1.3.1 Overview

The search identified six publications that report results of RCTs of PMR that met the inclusion criteria. One study, however, included some patients that were also included in other trials. Quality scores ranged from 2 to 4 (of a possible 4). Notably, three trials were double-blinded [Leon, 2004; Salem, 2004; Stone, 2002]. None of the reports reviewed showed improved mortality, and four indicated angina relief. Other benefits found in some trials were quality of life and exercise time.

One study was conducted at a single center, another included patients just from two centers, and the other three were multi-center. Each study included more than 100 patients.

Mean age ranged from 61 to 65 years. Prevalence of prior myocardial infarction ranged from 63 percent to 72 percent of patients. All patients included had angina class III or IV.

Of the three double-blinded PMR trials, no relative improvement in angina was found in two [Leon, 2004; Stone, 2002], while significant benefit was identified in one [Salem, 2004]. As noted below in the summaries, studies of PMR are heterogeneous with regard to patient population (e.g., presence of bypassable lesions), equipment/procedures used, and follow-up approach.

#### 4.1.3.2 Summaries

Gray and colleagues [Gray, 2003] reported data from a single-center UK trial in which 73 patients were randomized to receive either PMR or medical therapy. Twenty-one of those patients were included also in the Potential Class Improvement from Intramyocardial Channels (PACIFIC) trial (see below). Inclusion criteria were: stable angina pectoris (class III or IV), unsuitable for conventional revascularization, evidence of reversible ischemia by thallium-201 scintigraphy, EF of ≥ 25 percent, and myocardial wall thickness ≥ 8 mm. Patients were followed up at 3, 6, and 12 months. The primary end point was exercise time. Secondary end points included angina scores, LVEF, quality of life, changes in medical therapy, and hospitalizations. No peri-procedure deaths occurred among the 36 patients randomized to PMR, while 12-month mortality was three percent for both groups. At 12 months, exercise times were higher by 109 seconds in the PMR group, but lower by 62 seconds in the control group. Angina scores improved by two classes in 36 percent of PMR-treated patients at 12 months compared with zero percent of the control patients. Quality of life according to the SAQ was significantly better in PMR subjects.

Leon has reported the results of a 298 patient RCT of the Biosense PMR system versus medical therapy. Patients with functional class III or IV were divided into three arms (placebo = 102, low dose = 98, high dose = 98). Low-dose patients received 10–15 channels/zone and high-dose patients received 20–25 channels/zone. The 102 patients in the placebo group received a sham procedure. No crossovers were allowed. Mortality was similar among the groups. Major adverse cardiovascular event-free survival at 30 days significantly favored the placebo arm. No difference in improvement in functional classes (i.e., by two or more classes) was observed among the three groups. Exercise duration among the three groups was not significantly different. In terms of magnitude of ischemia, as assessed with SPECT, no consistent differences that would suggest a therapeutic effect were noted.

Oesterle and colleagues have reported the results of the PACIFIC trial [Oesterle, 2000]. In this trial, investigators randomly assigned 221 patients with refractory angina (135 class III and 86 class IV) and reversible perfusion defects on thallium stress testing to either PMR with continued medical treatment or to medical treatment alone. A total of 11 patients died during the follow-up period (eight PMR, three control). Overall survival showed no significant difference between the groups. In the PMR group, exercise duration increased by a median of 89 seconds as compared with an increase of 12.5 seconds in the control group. In addition, the CCS class assigned by the investigators decreased by at least two classes in 46 percent of patients assigned to PMR compared with only 11 percent of control patients. Quality of life, measured using the SAQ, was significantly better in the PMR than in the medically treated group at 1 year. As with all trials, assignment of anginal class was not blinded. Notably, the investigators examined ways in which this may have introduced bias by comparing the investigators’ assessments of angina class with those made by an independent panel without knowledge of treatment assignment. Results indicated that study investigators assigned significantly lower CCS scores to PMR patients than did the blinded panel. However, grades from the blinded panel were still significantly lower with PMR than with medical therapy.

Recently, Salem and colleagues reported results of the Blinded Evaluation of Laser Intervention Electively for Angina Pectoris (BELIEF) trial, a Norwegian RCT involving two centers [Salem, 2004]. A total of 82 patients were randomized to PMR using the Eclipse system or to a sham procedure and were followed for improvement in CCS functional class, exercise tolerance, and quality of life. An exclusion criterion in this trial was unstable angina requiring hospitalization within 14 days of change of medication. More than 80 percent of patients were in functional class III at baseline. There were no deaths in the PMR group through 1 year, with two deaths in the sham group (4.8 percent). This difference was not statistically significant. At 6 months, 41 percent of patients in the PMR group improved by two or more CCS classes compared with only 13 percent in the control group. There was no significant difference in exercise duration between the two groups, although patients in the control group had a faster onset of chest pain. Furthermore, there appeared to be a mild improvement in quality-of-life scores in favor of the PMR group.

Stone and colleagues have reported the results of the Prospective, Multicenter, Randomized trial of PMR in Patients with Nonrecanalizable Chronic Total Occlusions [Stone, 2002]. A total of 141 patients with class III to IV angina and a non-recanalizable chronic total occlusion were randomized to either PMR with the Eclipse system or to maximal medical therapy. Randomization took place after an unsuccessful, uncomplicated attempt to cross the chronic occlusion. Blinding was achieved through heavy sedation, dark goggles, and the concurrent performance of PCI in all patients. To assess the adequacy of blinding, patients completed a questionnaire before discharge regarding their belief about treatment assignment. Symptom-limited stress testing was performed at baseline and at 6 months. No significant differences between control and intervention were found for mortality (nine percent in both groups), angina class improvement, or revascularizations. The primary end point was the change in total exercise time from baseline to follow up. Exercise time improved by 62 seconds in the PMR group and by 54 seconds in the medical therapy group; however, this was not statistically significant.

Whitlow and colleagues have published the results of an RCT involving 330 patients with class III or IV rejected for conventional revascularization. Subjects were randomized to receive either PMR using the Eclipse system or maximum medical therapy or [Whitlow, 2003]. Patients were followed up at 3, 6, and 12 months. Mortality was similar between groups at 1 year (7.9 percent, PMR vs. 6.7 percent, medical therapy). Patients who underwent PMR had statistically greater improvements in exercise duration (mean change from baseline 100 seconds longer for PMR vs. 20 seconds shorter for medical therapy). PMR patients’ angina classification improved significantly, as well as the proportion of patients with an improvement of at least two functional classes at 1 year (38 percent vs. 19 percent). Quality of life, measured using the DASI, was significantly better for PMR patients at 1 year.

## 4.2 Safety and Utilization – Observational Studies

### 4.2.1 TMR

#### 4.2.1.1 Overview

Fifteen observational studies satisfied inclusion criteria for this review. These studies reflected experience with over 2300 procedures. Eleven of the studies reported single-center data. Two studies analyzed data obtained from registries.

In terms of length of follow up, two studies, including one of the registry studies, followed patients to 30 days only. Thirteen studies followed patients up to 1 year. One study evaluated outcomes to a mean of 5 years. Mean patient age ranged from 57 to 67 years.

Short-term (30-day) mortality ranged from three percent to 15 percent. One-year mortality ranged from 15 percent to 26 percent. Beyond this, Schneider and colleagues [Schneider, 2001] reported a 36 percent mortality at 36 months, and, based on 5-year follow-up of a large multicenter observational study, Horvath noted a 42 percent mortality [Horvath, 2003].

Four of these observational studies included data both for patients who received TMR as sole therapy or TMR combined with CABG [Burns, 1999; Guleserian, 2003; Peterson, 2003; Schneider, 2001].

Two of the studies were based on registries that allowed examination of trends and outcomes in community practice. Both were the largest in terms of number of cases included and participating centers. One of the registries was conducted outside of the US and prior to the randomized trial experience. The other registry was retrospective, involving passive 30-day reporting from sites that participated voluntarily.

Some differences between the characteristics of included patients were identified between these two works and the other works. The percentage of patients in angina class III or IV was approximately 75 percent, while in other observational studies nearly all were in the most severe angina classes. (As noted above, randomized controlled trials used angina class III/IV as an inclusion criterion.) Another apparent difference in the patients reported in observational studies compared to patients in clinical trials is that LVEF is slightly lower and unstable angina more prevalent.

Though these studies were not examined specifically for evidence of treatment efficacy, before/after comparisons often showed reductions in angina score. Of the 15 studies identified, 10 showed an improvement in angina symptoms, and only three of them could not identify significant differences from baseline through follow up. Improvement in angina symptoms tended to be higher at 6 months, persisting usually at least 12 months. TMR has also been associated in those works with improvements in quality of life, decreased medication usage, reduced hospital admissions, and improved exercise tolerance.

#### 4.2.1.2 Summaries

Two reports were based on information extracted from TMR registries. Peterson and colleagues identified 3717 patients receiving TMR using either the FDA-approved CO_2_ or Ho:YAG laser system at 173 US hospitals participating in the STS National Cardiac Database [Peterson, 2003]. From 1998 to 2001, the number of sites performing TMR increased from 33 (seven percent of total STS sites) to 131 (36 percent of total). The volume of procedures per site also increased during this period. Overall mortality rate of TMR as sole procedure was 6.4 percent. Operative risks were significantly higher in those patients with recent myocardial infarction, unstable angina, and depressed ventricular function. Patients without recent myocardial infarction, unstable angina, or depressed ventricular function had an operative mortality rate of 3.7 percent.

Burns reported data from 16 of the 22 centers in Europe and Asia registered with the Transmyocardial Laser Revascularization International Registry using a CO_2_ laser [Burns, 1999]. Data were collected prior to the US randomized trials to support FDA approval. TMR operative details were available on 932 patients. One hundred and seventy-seven cases had TMR combined with CABG, and 11 with percutaneous transluminal coronary angioplasty (PTCA). There was a high variation across centers in reporting information and follow up. In-hospital death rate was 9.7 percent. Other early complications were consistent with similar cardiothoracic surgical procedures. There was a decrease of two or more CCS angina classes in 47.3 percent, 45.4 percent, and 34·0 percent of survivors at 3, 6, and 12 months follow up, respectively. Preoperative treadmill exercise time was 6 minutes. This increased by 42 seconds at 3 months, 1 minute 43 seconds at 6 months, and 1 minute 50 seconds at 12 months.

Agarwal and colleagues have reported results from 102 patients who underwent isolated TMR using an CO_2_ laser at a single center in India [Agarwal, 1999]. The early mortality was 15 percent. At 1 year there was significant improvement in angina class and effort tolerance, but no significant change in LVEF; mortality at 12 months was 17 percent.

Allen and colleagues presented information on 42 patients with refractory angina who received Ho:YAG TMR, were not candidates for PTCA or CABG, had either CCS class IV angina (n = 23) or unstable angina (n = 19), and were unable to be weaned from intravenous nitroglycerin [Allen, 1998]. Peri-operative mortality was 12 percent, with no late deaths. At 3-month (n = 33) and 6-month (n = 21) follow up the mean angina class was 1.5 ± 0.1 and 1.1 ± 0.1, respectively.

Burkhoff and colleagues [Burkhoff, 1999b] assessed outcomes of 132 patients with severe angina who underwent TMR as sole therapy with a CO_2_ laser in a single center. Approximately half of the patients enrolled had unstable angina. Thirty-day and 12-month mortality were, respectively, 12 percent and 22 percent.

Dowling and colleagues have reported outcomes of Ho:YAG TMR performed in 85 class IV patients, all with unstable angina, at 14 centers [Dowling, 1998]. Operative mortality was 12 percent, and 12-month mortality was 22.4 percent. At 3 months, 86 percent of patients had class II angina or better. At 6 and 12 months, 77 percent and 75 percent of patients, respectively, had class II angina or better. Mean angina class at 6 months was 1.5 ± 1.1 and was 1.6 ± 1.3 at 12 months.

Hattler and colleagues reported outcomes of CO_2_ TMR performed in 76 patients with unstable angina and compared their outcomes with 91 stable patients receiving TMR during the same period [Hattler, 1999]. Operative mortality was 16 percent in unstable patients and three percent in stable patients. One-year mortality was 26 percent in unstable patients and 14 percent in stable patients; however mortality between 30 days and 1 year was similar between groups (13 percent and 11 percent). Significant improvement in angina class (two or more classes from baseline) was observed in patients who received TMR while unstable at 3 months (69 percent), and at 6 and 12 months (82 percent and 82 percent), and was similar to stable patients who received TMR.

Horvath and coworkers [Horvath, 1997] presented data from 200 patients at eight US hospitals. TMR was used as the sole therapy for patients with ischemic heart disease not amenable to PTCA or CABG. TMR was performed with a CO_2_ laser. The patients were followed for a combined 1560 months (mean 10 ± 3 months per patient). Their mean age was 63 years and their EF was 47 percent. The peri-operative mortality was nine percent. Angina class decreased significantly from before treatment to 3, 6, and 12 months. A significant decrease in the number of perfusion defects in the treated LV free wall was observed, as well as a decrease in the number of admissions for angina in the year after the procedure when compared with the year before treatment. Recently, Horvath and colleagues have published a 5-year follow up. From the original enrolment, patients who were lost, died, or received an additional revascularization procedure were excluded for this analysis. The results for the remaining group of 78 show that after an average of 5 years, the average angina class significantly improved to 1.6 ± 1. Sixty-eight percent of patients experienced a decrease in angina of at least two classes, and 17 percent were angina-free. Five-year SAQ scores revealed an average improvement of 170 percent over the baseline results.

Nagele and colleagues reported the results of a total of 60 patients who suffered from refractory angina that could not be revascularized by conventional methods who were suggested for TMR [Nagele, 1998]. Sole TMR was performed with a CO_2_ laser. In 126 candidates for the procedure, their refractory status was confirmed by checking antianginal medication and increased when possible. Patients were reevaluated between 1 and 2 months later. The decision to proceed with the TMR was then made. Medical management by intensification of drug treatment was possible in about 50 percent of patients initially submitted for TMR. After 3 months the CCS fell from 3.31 ± 0.51 to 1.84 ± 0.77 in 49 patients, but increased in the total group to 2.02 ± 0.92 after 6 months (n = 47), to 2.26 ± 0.99 after 1 year (n = 42), to 2.47 ± 1.11 after 2 years (n = 38), and to 2.58 ± 0.9 after 3 years (n = 19). MIBI/PET data at rest and after 6 months was worse in the TMR group. The peri-operative mortality was 12 percent. Mortality after 1 and 3 years was 23 percent and 30 percent, respectively. There was a high rate of cardiac events and new procedures.

Guleserian and coworkers [Guleserian, 2003] reported during a 24-month period 81 consecutive high-risk patients at a single center who underwent either sole therapy TMR (n = 34) or TMR with CABG (n = 47) using a Ho:YAG laser. High-risk patients were considered as those with EF ≤ 40, unstable angina, or congestive heart failure. Patients were demographically similar, except that sole TMR therapy patients were more likely to have had prior CABG than were CABG plus TMR or CABG-alone patients (96 percent, 24 percent, and 15 percent, respectively) and a significantly higher incidence of prior myocardial infarction (75 percent, 56 percent, and 35 percent, respectively). For sole therapy TMR, quality of life was diminished comparing TMR with CABG and CABG only. In the TMR group, 30-day mortality was nine percent; after CABG plus TMR, it was four percent.

Schneider and colleagues [Schneider, 2001] assessed outcomes of 41 patients at a single center in Germany who underwent TMR using a Ho:YAG-laser, 14 as TMR alone and 27 with additional CABG. Follow up was obtained at 6, 12, 18, 24, and 36 months in this prospective study. Only 50 percent of TMR alone patients (n = 8) and 22 percent of combined TMR and CABG patients (n = 6) were available for long-term follow up. TMR CCS class improved up to 18 months postoperatively, and after 24 and 36 months postoperatively there was absence of a positive effect of TMR: the CCS class decreased to 2.4 as compared to 3.5 preoperatively. After a combined CABG and TMR there was a significant decrease in angina at all times. The CCS functional class in these patients was 1.7 at 36 months as compared to 3.5 preoperatively. There was no significant change in exercise tolerance as compared to preoperatively. LVEF did not improve in either of the groups. Thallium scintigraphy indicated no improvement in myocardial perfusion in laser treated areas. Mortality rates at 36 months were 36 percent in the TMR group and 11 percent in the combined TMR plus CABG group.

Five trials have reported information from 21, 34, 34, 15, and 16 patients, respectively, at single centers who received TMR as sole therapy [Cooley, 1996; De Carlo, 2000; Landolfo, 1999; Lee, 2000; Muxi, 2003]. Thirty-day mortality in those studies ranged from three percent to 10 percent. Twelve-month mortality was 13 percent to 24 percent. All these studies identified angina improvements in patients receiving TMR. In the study by Landolfo and colleagues, despite the lack of demonstrable improvement in myocardial perfusion, TMR improved symptoms, although the maximal improvement was seen at 6 months post-TMR. Muxi and colleagues reported a significant decrease in angina at 3, 6, and 12 months from baseline, with a significant improvement in myocardial perfusion in laser-treated areas.

### 4.2.2 TMR with CABG

#### 4.2.2.1 Overview

Six observational studies of TMR plus CABG met the inclusion criteria. Four of them reported data on patients who received CABG plus TMR together with data on patients who received only TMR. Mean age in these studies ranged from 61 to 65 years. Previous myocardial infarction was reported in 50 to 77 percent of patients. Fifty-eight to 100 percent of patients had angina class III/IV, and EF ranged from 33 to 51 percent.

#### 4.2.2.2 Summaries

Gregoric and colleagues [Gregoric, 2003] reported data on 17 patients who underwent TMR CO_2_ laser combined with CABG. The patients had a mean age of 63 years and a mean EF of 33 percent. All but one patient had undergone previous coronary surgery. The mean follow-up period was 6.2 months. One patient died. At follow-up examination after a mean of 6 months (range, 2 to 9 months), 15 patients remained free of angina and one had mild angina. None had required further hospitalization.

The 47 high-risk patients assessed in the single-center study conducted by Guleserian and colleagues experienced a four percent 30-day mortality [Guleserian, 2003].

Peterson and colleagues analyzed the STS registry reported data from 2475 patients who received TMR combined with CABG [Peterson, 2003]. Overall operative mortality in this group was 4.2 percent. When considering patients without recent myocardial infarction, unstable angina, or depressed LVEF, the operative mortality rate was 2.6 percent. This study also compared 390 patients in the STS database who received CABG plus TMR with a control group created from 39,000 CABG-only patients with triple-vessel disease who received fewer than three grafts. Operative mortality was similar between groups.

Stamou and colleagues [Stamou, 2002] have reported the results of 30-day and 3-, 6-, and 12-month clinical follow-up after CABG plus Ho:YAG or CO_2_ TMR in a consecutive series of 169 patients with refractory angina pectoris and at least one myocardial ischemic area not amenable to CABG. One-year survival and event-free survival were 85 percent and 81 percent, respectively. At the end of the first year after the procedure, seven patients (four percent) had angina class III/IV versus 152 patients (90 percent) at baseline.

Long-term mortality (36-month) identified by Schneider and colleagues in a group of 27 patients was 11 percent [Schneider, 2001]. There was a significant decrease in angina at all times. The CCS functional class in these patients was 1.7 at 36 months as compared to 3.5 preoperatively.

Wehberg and colleagues have published the results of a single-center retrospective analysis of 6-month follow up of 255 consecutive patients who received either CABG alone (n = 219) or CABG and TMR (n = 36). TMR was performed in non-graftable regions. Patients had CCS angina scores III or IV and EF ≥ 30 percent. Age and EF were similar for both groups, although a significantly higher percentage of patients in the CABG group had congestive heart failure (28 percent vs. eight percent). One-month mortality was similar in both groups (2.3 percent in postoperative angina scores were similar in both groups. the CABG group and zero percent in the CABG plus TMR). Other major adverse outcomes were also similar in the two groups. One-month

### 4.3.2 PMR

#### 4.3.2.1 Overview

Two observational studies of PMR were identified. Mean age was 61 and 62 years, prior myocardial infarction was present in 60 percent and 68 percent of patients, and mean EF was 38 percent and 48 percent. Only one of these studies reported baseline angina class. Both studies report 6-month follow up. No deaths were reported during this period in either study.

#### 4.3.2.2 Summaries

Kaul and colleagues reported information from 35 patients from a single center in India with zero percent mortality after a 6-month follow up after PMR treatment with the Eclipse device [Kaul, 1999]. All patients were reported to have class III or IV angina prior to PMR; at 3 months mean angina class was 0.94 ± 0.65, and at 6 months mean angina class was 1.08 ± 0.58.

Kornowski and colleagues presented data from 77 patients treated at three US hospitals with PMR using the Biosense device [Kornowski, 2000]. There were no deaths at 6 months. Exercise duration significantly increased from 387 ± 179 seconds at baseline to 479 ± 161 seconds at 6 months. The time to onset of angina increased significantly from 293 ± 167 seconds at baseline to 414 ± 169 seconds at 6 months. Time to ST-segment depression (greater than 1 mm) also increased significantly from 327 ± 178 seconds at baseline to 436 ± 175 seconds at 6 months. Angina by CCS class improved from 3.3 ± 0.5 at baseline to 2.0 ± 1.2 at 6 months.