# METHODS

## 3.1 Overview of the Literature Search

A search of the MEDLINE and PubMed databases was conducted. The International Network of Agencies for Health Technology Assessment (INAHTA) database (www.inahta.org) and National Guideline Clearinghouse (www.guideline.gov) were searched for technology assessments and guidelines. Evidence-based medicine reviews and the Cochrane Central Register of Controlled Trials were searched to obtain additional reviews and trials not captured in the initial search. References from recent reviews and technology assessments were reviewed for additional pertinent articles.

A horizon scan was conducted by searching ClinicalTrials.gov (www.clinicaltrials.gov) and Current Controlled Trials (www.controlled-trials.com).

## 3.2 Literature Search Strategy

Due to the broad nature of the report and the relatively limited scope of the literature on the topic, we decided to conduct basic keyword searches, limiting results by “English language” and “human subjects.” The search strategy was as follows:

Database: Ovid MEDLINE(R) <1966 to May Week 1 2004>

1. transmyocardial revascularization.mp. (123)
2. transmyocardial laser revascularization.mp. (321)
3. percutaneous myocardial laser revascularization.mp. (14)
4. percutaneous myocardial revascularization.mp. (19)
5. 1 or 2 or 3 or 4 (427)
6. limit 5 to (human and english language) (263)

To limit the literature to the most useful and pertinent studies, the following criteria were used to exclude irrelevant abstracts:

- Study has fewer than 12 patients;
- Study does not have human subjects;
- Abstract is not in English;
- 30-day mortality is not reported.

## 3.3 Results of the Literature Search

The search of the MEDLINE and PubMed databases yielded 263 abstracts for review. Review of these abstracts produced 56 articles for full-text review. Updated searches, review of references, and suggestions from AHRQ and peer reviewers uncovered an additional 19 articles. Full-text review utilized the same general exclusion criteria as were used during abstract review. Articles were categorized as RCTs or observational studies (which included cohort studies and case series). Inclusion criteria for the articles were as follows:

RCTs: Trial reports efficacy of TMR or PMR in terms of angina and/or survival.

Observational studies:

1. Surgical complications related to TMR or PMR are reported, including mortality and other serious complications such as tamponade, re-operation, and infection.
2. The nature of utilization of TMR or PMR is mentioned (i.e., alone vs. with CABG, patient eligibility criteria).

Two physicians – one an MD/PhD (methodologist), and the other an MD (cardiologist) – independently reviewed the articles and extracted general information on objectives, design, participants' age, and outcomes. Detailed information was extracted only from studies that met the major inclusion criteria, and data were collected on study design. RCT study quality was assessed using the Jadad score [Jadad, 1996] modified to suit the technologies under consideration here (Appendix 8.3).

Observational study quality was assessed using the criteria described by Sackett [Sackett, 2000], also modified to more directly apply to the technologies at hand (Appendix 8.3). Disagreements were resolved by consensus, and a third physician was consulted to decide any remaining questions.

After applying inclusion criteria to the full-text articles, 38 publications, representing 14 RCTs, 21 observational studies, and three follow-up reports of other studies were included. These articles are described in the “Results” section below, with abstracted data provided in the evidence tables (Appendix 8.4).

Evidence tables for all included articles are provided in Appendix 8.4. Data abstracted from each article include:

- Study characteristics – including location, number of centers, type of laser used, number of channels created, whether enrollment was consecutive, and length of follow up.
- Patient characteristics – including number of subjects (men and women), mean age, race and angina class, inclusion and exclusion criteria, patient history, and physical examination findings.
- Results – including mortality (30-day and other time points), mean angina class, and other outcomes reported (such as improvement of two or more CCS classes, exercise time).
- Quality score – as described above, a quality score was assigned to each article, including any notes of important details of the study not captured elsewhere in the evidence table.

The horizon scan found no relevant studies to be currently underway.

## 3.4 Important Issues Considered

Two issues were considered by the authors of this review to be especially relevant to the evaluation of TMR and PMR and were given special attention in this evidence summary. First, the placebo effect is potentially powerful influence in response. The presence and nature of blinding are accordingly detailed in the evidence tables. Second, because of concern about a mechanism of action, each study was specifically examined for ancillary results that might shed light on this issue.