# BACKGROUND

## 2.1 Background and Rationale for Use of the Technologies

Sen and colleagues first described transmyocardial revascularization using hollow needles in 1965 [Sen, 1965]. This technique attempted to mimic reptilian hearts, which are predominantly perfused by endothelium-lined channels that fill directly from the ventricular cavity [Allen, 1999; Huikeshoven, 2002]. Since Sen’s pioneering work, investigators have examined other methods for channel creation including drills, ultrasound, cryotherapy, radiofrequency, and saline jets [Huikeshoven, 2002]. These experiments eventually resulted in Mirhoseini and colleagues’ 1981 report of transmyocardial revascularization using laser irradiation [Mirhoseini, 1981]. Because the carbonization associated with its use was observed to inhibit lymphocyte, macrophage, and fibroblast migration, laser revascularization was felt to promote less scar formation and better patency than pure mechanical methods [Huikeshoven, 2002].

Since their development, laser techniques have supplanted the other methods and have become the standard for myocardial revascularization. There are now two approaches for laser revascularization: surgical and percutaneous. The surgical approach for TMR was described first and generally involves a left anterior thoracotomy to permit direct application of the laser probe on the myocardium. Surgical TMR using minimally invasive techniques has also been reported [Trehan, 1998]. With the probe, a series of channels (approximately 25 to 40) are created transmurally from the epicardial surface [Saririan, 2003]. Digital pressure usually controls external bleeding, but sutures must sometimes be placed in the epicardium for hemostasis [Allen, 1999; Frazier, 1999].

More recently, percutaneous approaches to laser revascularization have also been developed. PMR employs catheter-based laser systems that are introduced into the left ventricle from the femoral artery. The laser probe is guided by fluoroscopy to the endocardium surface, where pulses are delivered to create channels [Saririan, 2003]. In contrast to TMR, which creates transmural channels from the epicardial surface, PMR devices operate from the endocardial surface and are designed to penetrate less than the full wall thickness [Saririan, 2003]. The typical PMR probe channel measures 5–6 mm deep in walls of at least 8 mm thickness [Saririan, 2003].

## 2.2 FDA and CMS Status

The CMS Coverage Issues Manual describes the indications for which TMR is covered by CMS. The following excerpt from the coverage manual describes the status of TMR coverage:

…as a late or last resort for patients with severe (Canadian Cardiovascular Society classification Classes III or IV) angina (stable or unstable), which has been found refractory to standard medical therapy, including drug therapy at the maximum tolerated or maximum safe dosages. In addition, the angina symptoms must be caused by areas of the heart not amenable to surgical therapies such as percutaneous transluminal coronary angioplasty, stenting, coronary atherectomy or coronary bypass. Coverage is further limited to those uses of the laser used in performing the procedure which have been approved by the Food and Drug Administration for the purpose for which they are being used.

Patients would have to meet the following additional selection guidelines:

1. An ejection fraction of 25% or greater;
2. Have areas of viable ischemic myocardium (as demonstrated by diagnostic study) which are not capable of being revascularized by direct coronary intervention; and
3. Have been stabilized, or have had maximal efforts to stabilize acute conditions such as severe ventricular arrhythmias, decompensated congestive heart failure or acute myocardial infarction.

Coverage is limited to physicians who have been properly trained in the procedure. Providers of this service is performed must also document that all ancillary personnel, including physicians, nurses, operating room personnel and technicians, are trained in the procedure and the proper use of the equipment involved. Coverage is further limited to providers which have dedicated cardiac care units, including the diagnostic and support services necessary for care of patients undergoing this therapy. In addition, these providers must conform to the standards for laser safety set by the American National Standards Institute, ANSIZ1363 [CMS, 2004].

FDA-approved lasers and their uses are outlined in the next section of this report (Section 2.3).

PMR is not currently covered by CMS. The application for pre-market FDA approval for PMR was denied in March, 2004, though further efforts are ongoing to obtain FDA approval for the technology [CardioGenesis, 2004].

## 2.3 Current Technology

Three types of lasers have been examined in clinical trials: carbon dioxide (CO_2_); holmium: yttrium-aluminum-garnet (Ho:YAG); and xenon chloride (XeCl) excimer. The latter two types may be used with fiber-optic catheters and therefore can be applied in percutaneous or thoracoscopic approaches [Abo-Auda, 2003]. The FDA has approved only Ho:YAG (CardioGenesis Corporation) and CO_2_ lasers (PLC Medical Systems) for use with TMR.

### 2.3.1 CO_2_ Lasers

These lasers were the first type used for TMR and operate in the infrared range of the light spectrum [Huikeshoven, 2002]. CO_2_ systems cannot be employed through optical fibers and therefore are limited to use in surgical TMR.

### 2.3.2 Ho: YAG Lasers

These lasers were the second type developed for TMR and deliver energy in the mid infrared range through an optical fiber [Huikeshoven, 2002]. Because these systems utilize an optical fiber, they may be employed with PMR in addition to TMR.

Three systems using Ho:YAG lasers (Biosense, Eclipse, CardioGenesis) have been examined in clinical studies of PMR, though to date none have been approved by the FDA. The Biosense system (Johnson & Johnson) does technically differ from the other two systems in that it lases from the endocardial surface, rather than from within the myocardium after physical puncture of the endocardium.

### 2.3.3 XeCl Excimer Lasers

Excimer lasers work in the ultraviolet range and are the least clinically tested type of lasers in this context [Huikeshoven, 2002]. These lasers have not been approved by the FDA.

## 2.4 Possible Mechanisms of Action

The possible mechanism of action for TMR and PMR remains controversial. As the open channel hypothesis has fallen by the wayside, the three most popular proposed mechanisms are angiogenesis, cardiac denervation, and the placebo effect.

As a comprehensive review of the experimental data is beyond the scope of this work, these potential mechanisms are described only briefly below.

### 2.4.1 Creation of Patent Endocardial Channels

The initial rationale for TMR and PMR was creation of patent channels from the left ventricular (LV) cavity to provide oxygenated blood directly to the myocardium. The data to support this mechanism are controversial, but the preponderance of experimental evidence refutes this hypothesis.

While some experimental studies have reported persistently patent channels in the days to weeks following TMR procedures, most pathologic studies have shown that clot formation causes occlusion of TMR channels within days of the procedure [Fisher, 1997; Hardy, 1987; Saririan, 2003; Whitaker, 1999]. Moreover, most studies have shown no acute improvement in perfusion following TMR, which would be expected if patent channels were the predominant mechanism of action [Saririan, 2003; Whitaker, 1999].

In the weeks that follow, some of these channels may re-open, though the reason some open and others close is not known. Most studies involving follow up over several months have reported lack of channel patency [Huikeshoven, 2002; Whitaker, 1999], but a minority of studies has reported evidence for patent channels [Whitaker, 1999]. These few studies claiming patent channels have also reported significant recoil and dimunition of channel size from 1 mm at creation to 75 μm at follow up [Whitaker, 1999].

However, even if patency were maintained, investigators have argued that the channels created by TMR could not contribute in any meaningful way to perfusion. First, Pifarre and colleagues have shown that since LV cavity pressure is usually less than the intramyocardial pressure surrounding TMR channels, the latter could not be filled from the former [Huikeshoven, 2002; Pifarre, 1969]. Second, since the internal surface area of TMR channels is less than 0.01 percent of the capillary internal surface area, any blood flow would contribute only minimally to oxygenation [Huikeshoven, 2002]. For these theoretical reasons, and because of the lack of significant clinical or experimental reasons in its support, this proposed mechanism of action has been largely abandoned.

### 2.4.2 Stimulation of Angiogenesis

Following TMR procedures, animal studies have shown increased vascular density within TMR scar [Huikeshoven, 2002; Whitaker, 1999]. These findings have led to the hypothesis that TMR may act by stimulating angiogenesis. TMR has been reported to upregulate vascular endothelial growth factor (VEGF) messenger ribonucleic acid (RNA) and increase expression of other growth factors [Horvath, 1999; Chu, 1999]. Whether this is a specific effect of laser irradiation or a non-specific response to tissue injury is unclear [Chu, 1999]. In either case, data regarding the extent of new vessel growth (whether confined to the TMR channels or extending into the surrounding tissue) have been controversial [Huikeshoven, 2002].

The angiogenesis hypothesis is indirectly supported by animal studies demonstrating no immediate post-procedure perfusion changes but an improved blood flow after 4 to 26 weeks [Bridges, 2004; Huikeshoven, 2002]. Improved perfusion has been reported with all three available laser types in both canine and porcine models [Hughes, 2000; Huikeshoven, 2002; Martin, 2000; Yamamoto, 1998]. However, these findings have not been consistently replicated in humans. While some studies have reported better perfusion at follow up [Frazier, 1999], others have not demonstrated significant improvement [Allen, 1999; Burkhoff, 1999].

### 2.4.3 Myocardial Denervation

Because angiogenesis requires some time for new vessel growth, this mechanism cannot explain the angina relief that some patients may experience within days of treatment. One possible explanation for this acute pain relief is cardiac denervation. According to this hypothesis, the laser irradiation and consequent thermal tissue effects produce damage in the heart’s sympathetic nerve fibers.

Several experimental studies have demonstrated destruction of cardiac nerve fibers with TMR at 2 to10 weeks [Arora, 2001; Huikeshoven, 2002; Kwong, 1997; Le, 2000; Yamamoto, 2000]. However, other experimental studies have not found evidence for denervation [Hirsch, 1999; Hughes, 1999]. In one porcine experimental study, there was evidence for regional denervation at 3 days post-operatively with re-innervation at 6 months [Hughes, 2004]. In one of the few clinical studies of denervation, Al-Sheikh and colleagues found that six of eight patients had positron emission tomography (PET) evidence for increased denervation defects following TMR [Al-Sheikh, 1999]. In 1-year follow-up exercise testing of patients who had originally been randomized to TMR or placebo and those randomized to PMR or placebo, Myers and colleagues found no echocardiographic evidence for increased silent ischemia in the TMR and PMR groups [Myers, 2002].

### 2.4.4 Placebo Effect

Because of the conflicting experimental and clinical evidence for a definite mechanism of action, a placebo effect has been proposed as the etiology for the angina relief seen in clinical studies. Clinical TMR studies cannot be blinded because of the ethical dilemmas associated with sham surgery, but one double-blinded, randomized trial of PMR has been performed. In this study, angina relief in the PMR group was significantly higher than in the sham group [Salem, 2004]. In contrast, a larger PMR study (n = 298) with a different sham procedure showed no difference between groups [DIRECT, 2001].

### 2.4.5 Other

Besides the hypotheses described above, other proposed mechanisms of action for TMR include improved cardiac compliance because of scar formation and myocardial destruction allowing redistribution of blood flow [Huikeshoven, 2002].

## 2.5 Utilization

Although initially intended for patients not amenable to standard revascularization techniques, TMR has also been applied as an adjunct to conventional CABG or other cardiac procedures [Allen, 2000; Peterson, 2003]. The use of TMR as an adjunct to other cardiac revascularization is “off-label” from its current FDA indication.

In collaboration with the FDA and the Society of Thoracic Surgeons (STS), Peterson and colleagues reviewed the STS database for 1998 to 2001 to examine the use and safety of TMR in community practice [Peterson, 2003]. The STS database is a voluntary, multi-center clinical database that collects information from two-thirds of US cardiothoracic hospitals and has patient, clinical, and acute outcomes data on more than 2.1 million cardiothoracic procedures [Peterson, 2003].

This review found that more combined procedures (2475 TMR plus CABG, 581 TMR plus other cardiac procedures such as valve surgery) have been performed than TMR-only procedures (661) [Allen, 2000; Peterson, 2003]. By 2001, 131 (36 percent) of STS sites were performing TMR with a median volume of 12 procedures (range 1 to 150) during the 4-year study period [Allen, 2000; Peterson, 2003].