# INTRODUCTION

## 1.1 Overview

Over the last two decades, transmyocardial laser revascularization (TMR) and percutaneous myocardial laser revascularization (PMR) have been developed to treat refractory angina in patients with coronary artery disease that is not amenable to revascularization with percutaneous coronary intervention (PCI) or coronary artery bypass grafting (CABG). These new techniques create multiple, small channels in ischemic myocardium using laser irradiation with the goal of improving local blood flow.

## 1.2 Request by Centers for Medicare and Medicaid Services

The Agency for Healthcare Research and Quality (AHRQ), on behalf of the Centers for Medicare and Medicaid Services (CMS), has requested a technology assessment on TMR and PMR in preparation for a Medicare Coverage Advisory Committee meeting on this topic.

The specific aims of this technology assessment are as follows:

1. Provide a summary and description of the technology.
2. Review the peer-reviewed clinical literature on the outcomes associated with the use of:
  a. TMR as a stand-alone procedure;
  b. TMR used together with CABG;
  c. PMR.
3. Review of available information on clinical trials underway as a horizon scan for this technology.

In addition, studies on the mechanism of action and the specific lasers used for each of the procedures were reviewed, and a description of those findings is included in this report.

## 1.3 Organization of the Report

A background section provides an overview of how the technologies work, what lasers are used, and the status of the technologies in terms of Food and Drug Administration (FDA) approval and CMS coverage. In addition, several common hypotheses on the mechanism of action for laser revascularization are summarized.

Results are discussed under two main headings: efficacy and safety/utilization. To assess the efficacy of TMR and PMR, we reviewed randomized controlled trials (RCTs). For the more general questions of safety and utilization – phenomena that may not be well reflected in a trial setting – we focused on observational studies. Under each of the main headings, we provide an overview of all the studies in that section, followed by brief summaries of each study.