# Evidence Tables

Transmyocardial Revascularization – Randomized Controlled Trials

Transmyocardial Revascularization – Observational Studies

Transmyocardial Revascularization with CABG – Randomized Controlled Trials

Transmyocardial Revascularization with CABG – Observational Studies

Percutaneous Myocardial Revascularization – Randomized Controlled Trials

Percutaneous Myocardial Revascularization – Observational Studies