# Quality Score Description

## RCT Quality Score

The Jadad et al. (1996) instrument for assessing the quality of randomized clinical trials was used as the basis for developing the RCT quality score used in this report.

1. Randomized – was the study described as randomized (this includes the use of words such as randomly, random and randomization)
  - To receive a “1” the randomization must be described and appropriate, as described in Jadad, 1996
2. Blinded – was the study described as double blind
  - To receive a “1” the blinding must be described and appropriate, as described in Jadad, 1996
3. Withdrawals/ dropouts described – was there a description of withdrawals and dropouts
  - To receive a “1” the withdrawls/dropouts must be described
4. Targeting strategy defined – did the authors adequately describe the section of myocardium targeted for revascularization (where the channels were placed and why)
  - To receive a “1” the targeting strategy must be adequately described

## Observational Study Quality Score

The Sackett (1996) prognosis worksheet was used to develop the summative quality score for observational studies.

1. Patients identified at common point – Was a defined, representative sample of patients assembled at a common point in the course of their disease (at the point prior treatment failed).
  Examples of situations warranting a score of 0 for this quality point:
  - a mix of patients who failed and who have not failed;
  - inclusion of patients who fit a wide variety of definitions of failure
2. Sufficient follow-up – Was patient follow-up sufficiently long and complete? (≥ 30 days)
3. Blinded outcome assessment – Were objective outcome criteria applied in a “blind” fashion? (Angina assessed by someone other than the surgical team OR objective measures used – e.g. thallium stress test)
4. Measurement and adjustment for confounders – If subgroups with different prognoses are identified, was there adjustment for important prognostic factors?
5. Targeting strategy defined – did the authors adequately describe the section of myocardium targeted for revascularization (where the channels were placed and why)