# Study Summary Tables

## TMR alone

Table 1 Characteristics of RCT studies of TMR alone

Author | N | # centers | Mean age (yrs) | Quality Score (out of 4) | Previous MI (%) | III/IV (%) | LVEF (%) | 30- d mortality (%) | 12 m mortality (%) | Long term mortality (%) | Angina | Other
1. Aaberge | 100 | 1 | 63 | 2 | 70 | 100 | 49 | 4 | 12 | 23% (32–60 month) | + | Hospital, Exercise
2. Allen | 275 | 18 | 60 | 2 | 64 | 100 | 47 | 5 | 16 | 35% (5 year)^*^ | + | Events, QoL, Excercise
3. Burkhoff | 182 | 16 | 64 | 3 | 70 | 100 | 50 | 1 | 5 | NR | + | NR
4. Frazier | 192 | 12 | 61 | 1 | 80 | 100 | 50 | 3 | 15 | NR | + | Events, Perfusion, QoL
5. Huikeshoven | 30 | 1 | 63 | 1 | NR | NR | 55 | 0 | 7 | NR | + | QoL
6. Jones | 86 | 1 | 62 | 2 | 68 | NR | | 2 | 12 | NR | + | Exercise
7. Schofield | 188 | 1 | 60 | 2 | 74 | 100 | 48 | 5 | 11 | NR | + | Exercise
Total | 1053

* p = 0.05 Mortality in the TMR group compared with mortality in the control group.

Table 2 Characteristics of Observational studies of TMR alone

Author | N | # centers | Mean age (years) | Previous MI (%) | III/IV (%) | LVEF (%) | 30-d mortality (%) | 12-m mortality (%) | Angina
1. Agarwal | 102 | 1 | 57 | 32 | 54 | 45 | 15 | 17 | ND
2. Allen | 42 | 1 | 62 | 69 | 100 | 45 | 12 | NR | +
3. Burkhoff | 132 | 1 | 61 | NR | 100 | 44 | 12 | 22 | NR
4. Burns | 932 | 21 | 62 | 77 | 75 | 49 | 10 | NR | +
5. Cooley | 21 | 1 | 63 | 57 | NR | 48 | 10 | 24 | +
6. De Carlo | 34 | 1 | 67 | 88 | 59 | 47 | 3 | 15 | +
7. Dowling | 85 | 14 | 63 | 72 | 100 | 48 | 12 | 22 | +
8. Guleserian | 34 | 1 | 61 | NR | NR | NR | 9 | NR | ND
9. Hattler | 76/91 | 13 | 64/61 | 75/79 | 100/100 | NR | 16/3 | 26/14 | NR
10. Horvath | 200 | 8 | 63 | 78 | 100 | 45 | 9 | 18 | +
11. Horvath f/u | 78 | 13 | NR | NR | NR | NR | N/A | 42 (5 year) | +
12. Landolfo | 34 | 1 | 61 | 76 | 100 | 51 | 6 | 15 | +
13. Lee | 15 | 1 | 63 | 80 | 100 | 38 | 7 | 13 | +
14. Muxi | 16 | 1 | 60 | | 100 | 57 | 0 | 6 (6 months) | +
15. Nagele | 60 | 1 | 64 | 57 | 100 | 54 | 12 | 23 | ND
16. Peterson | 661 | 173 | 62 | 53 | 78 | 46 | 6 | NR | NR
17. Schneider | 14 | 1 | 65 | 57 | NR | 52 | 0 | 36 (36 months) | ND
Total | 2549

## TMR plus CABG

Table 3 Characteristics of RCT studies of TMR + CABG

Author | N | # centers | Mean age (years) | Quality Score (out of 4) | Previous MI (%) | III/IV (%) | LVEF (%) | 30- d mortality (%) | 12 m mortality (%) | Long term mortality (%) | Angina
Allen | 263 | 24 | 64 | 3 | 34 | NR | 51 | 1.5 | 5 | 24% (5 year) | ND

Table 4 Characteristics of Observational studies of TMR + CABG

Author | N | # centers | Mean age (years) | Previous MI (%) | III/IV (%) | LVEF (%) | 30-d mortality (%) | 12-m mortality (%) | Angina
1. Gregoric | 17 | 1 | 63 | 71 | 76 | 33 | 6 | 6 (6 m) | +
2. Guleserian | 47 | 1 | 61 | NR | NR | NR | 4 | NR | ND
3. Peterson | 2475 | 173 | 65 | 50 | 58 | 50 | 4 | NR | NR
4. Schneider | 27 | 1 | 64 | 77 | NR | 51 | 0 | 11 (36 m) | +
5. Stamou | 166 | 1 | 63 | 64 | 90 | NR | 8 | 15 | +
6. Wehberg | 36 | 1 | 63 | NR | 100 | 52 | 0 | NR | ND
Total | 2768

Table 5 Mortality in studies that compare TMR as sole therapy vs. TMR + CABG

Author | TMR (%) | TMR + CABG (%)
1. Guleserian (30 day) | 9 | 4
2. Peterson (30 day) | 6 | 4
3. Wehberg (30 day) | 2 | 0
4. Schneider (36 month) | 36 | 11
5. Burns (30 day) | 10 (no differentiated mortality data)

## PMR

Table 6 Characteristics of RCT studies of PMR

Author | N | # centers | Mean age (years) | Quality Score (out of 4) | Previous MI (%) | III/IV (%) | LVEF (%) | 30- d mortality (%) | 12 m mortality (%) | Angina | Other
1. DIRECT | 196 | Multi | 63 | N/A | NR | NR | NR | 4/8 | 11/14 | ND | Exercise, MACE
2. Gray | 73 | 1 | 61 | 3 | 72 | 100 | 48 | 0 | 3 | + | Exercise, QoL
3. Oesterle | 221 | 13 | 62 | 3 | 65 | 100 | NR | NR | 7 | + | Exercise, QoL
4. Salem | 82 | 2 | 66 | 5 | 63 | 100 | 64 | 0 | 0 | + | QoL
5. Stone | 141 | 17 | 65 | 4 | 65 | 100 | 52 | 0 | 9 | ND | NR
6. Whitlow | 330 | 20 | 63 | 3 | 67 | 100 | 47 | NR | 8 | + | Events, Exercise, QoL
Total | 843

Table 7 Characteristics of Observational studies of PMR

| N | # centers | Mean age (years) | 30-d mortality (%) | 6-m mortality (%) | Angina | Previous MI (%) | Class III/IV (%) | LVEF (%)
1. Kaul | 35 | 1 | 62 | 0 | 0 | + | 60 | 100 | 38
2. Kornowski | 77 | 3 | 61 | 0 | 0 | + | 68 | NR | 48
Total | 112

+ Study showed significant improvement in angina

ND: Study did not show significant improvement in angina

NR: Not reported