# Glossary

## Abbreviations used in the text

AHRQ: Agency for Healthcare Research and Quality
BELIEF: Blinded Evaluation of Laser Intervention Electively for Angina Pectoris
CABG: Coronary artery bypass grafting
CCS: Canadian Cardiovascular Society
CMS: Centers for Medicare and Medicaid Services
CO_2_: Carbon dioxide
DASI: Duke Activity Status Index
ECG: Electrocardiogram
EF: Ejection fraction
FDA: Food and Drug Administration
Ho_YAG: Holmium:yttrium-aluminum-garnet
INAHTA: International Network of Agencies for Health Technology Assessment
J: Joule
LV: Left ventricle (or ventricular)
LVEF: Left ventricular ejection fraction
MI: Myocardial infarction
mm: Millimeter
μm: Micrometer
NR: Not reported
NYHA: New York Heart Association
PACIFIC: Potential Class Improvement from Intramyocardial Channels
PCI: Percutaneous coronary intervention
PET: Positron emission tomography
PMR: Percutaneous myocardial laser revascularization
PTCA: Percutaneous transluminal coronary angioplasty
QoL: Quality of life
RCT: Randomized controlled trial
RNA: Ribonucleic acid
SAQ: Seattle Angina Questionnaire
SPECT: Single-photon emission computed tomography
STS: Society of Thoracic Surgeons
TMR: Transmyocardial revascularization
VEGF: Vascular endothelial growth factor
XeCl: Xenon Chloride