# RESULTS

## Projected Undiscounted Outcomes with Screening

Undiscounted outcomes associated with the screening strategies are presented in Table 7A for the MISCAN model and Table 7B for the SimCRC model. Without screening we project that 57 out of every 1,000 65-year old individuals will be diagnosed with CRC in their lifetimes. This induces approximately $3.4 to $4.0 million in lifetime direct medical costs ($60 to $71 thousand per CRC case). With screening, many of these CRC cases can be prevented assuming 100% adherence to screening regiments; the reduction in the lifetime risk of CRC ranged from 32–39% with annual FOBT (Hemoccult II) screening to 53–72% with 10-year colonoscopy screening (reported ranges describe differences between projections by model). Some of the benefit associated with the fecal-related tests is because of the false positive rate, which leads to individuals being placed on a colonoscopy schedule. In other words, some of the benefit of these tests can be attributed to the fact that a substantial number of individuals with false-positive test results are placed on 10-year colonoscopy. In the MISCAN model the combination of 5-yearly flexible sigmoidoscopy with an annual highly sensitive FOBT (Hemoccult SENSA or FIT) are the two most effective strategies, saving 153 life-years per 1000 persons screened. In the SimCRC model 10-yearly colonoscopy is most effective, saving 159 life-years per 1000 persons screened. For all screening strategies except the DNA stool test strategies, the costs of screening, follow-up and surveillance (including treatment of colonoscopy complications) are smaller than the savings from foregone treatment of prevented CRC cases. The DNA stool testing strategies under the base-case assumptions (i.e., version 1.0 and version 1.1 with a per-test cost of $350) were the most costly screening strategies. In addition, all but the 3-yearly version 1.1 strategy were less effective than annual Hemoccult II. Life-years saved varied from 58 to 122 per 1000 persons screened depending on the version of the DNA stool test, the screening interval and the simulation model used. The total costs ranged from $3.6 million to $5.2 million per 1000.

## Cost-Effectiveness Analysis from Payer Perspective

Table 8 shows the total discounted costs, discounted life-years gained, and the incremental cost-effectiveness ratios for 17 screening strategies, including no screening, for each model (results for a cohort of 50-year-olds are presented in Appendix 6). The models varied somewhat as to which tests were on the efficient frontier (i.e., were not ruled out by simple or extended dominance). Both models showed DNA stool test version 1.0 strategies to be the most expensive options when offered every three years at a cost of $350, and still more expensive than the other alternatives when offered at 5 year intervals. Under the DNA stool version 1.1 test assumptions, screening every three years with DNA stool testing resulted in more life-years gained than the cheapest test Hemoccult II. All other scenarios with the DNA stool test result in fewer life-years gained than the other tests (this finding true with both models). Figure 2 shows a plot of the discounted life-years gained (compared with no screening), the discounted lifetime direct medical costs (from the Medicare perspective), and the cost-efficient frontier, where each non-dominated strategy is compared with the next least expensive strategy.

Hemoccult II was cost-saving compared with no screening and this result was consistent for both models. There were several other strategies found to be cost-saving in the SimCRC analysis and near cost-saving in the MISCAN analysis (Table 8).

## Threshold Analyses

At the base-case cost for a DNA stool test of $350, none of the DNA stool test strategies were on the efficient frontier. Threshold analyses indicated that with the version 1.0 test assumptions, lowering the cost to $0 would not move the DNA stool test strategy to the frontier (Table 9). In order to be on the efficient frontier the DNA stool test version 1.1 can have a maximum unit cost of $34–$51 (based on MISCAN and SimCRC, respectively) when offered every 5 years, or $40–$60 (based on MISCAN and SimCRC, respectively) when offered every 3 years. The threshold costs are slightly higher when compared with no screening, and even higher when compared with the strategy with the highest ACER. In no case was the threshold cost as high as the base-case unit cost estimate of $350. (This finding held when evaluating DNA stool testing among a cohort of 50-year-olds—see Appendix 6).

## Sensitivity analyses

The threshold costs with varying sensitivity and specificity for the DNA stool test are shown in Table 9. Analysis with the SimCRC model identified no scenarios for which the threshold value of the cost of the DNA stool test could be greater than its base-case value of $350 and still be on the efficient frontier. With the MISCAN model, the cost of the DNA stool test may rise to $364 if the test is perfect with respect to sensitivity and specificity and if offered every 5 years. Our analysis showed that there were no other assumptions that yielded a threshold cost as high as $350. This was true whether comparing to other tests on an incremental cost-effectiveness basis or comparing with ACERs. For example, when comparing with ACER values of alternative screening strategies the unit cost of the DNA stool test has to be lower than $288 (SimCRC) or $324 (MISCAN), even if the test was perfect.

If individuals who would not be screened otherwise would get screened with a DNA stool test strategy, the cost-effectiveness of the DNA stool testing strategy test would improve. The threshold costs for the test to lie on the efficient frontier under varying adherence assumptions are shown in Table 10. Analyses with the MISCAN model showed that adherence has to increase to almost 75% (with other tests at 50%) for 3-yearly DNA stool testing to be on the frontier with the base-case cost of $350. Analyses with the SimCRC model showed that adherence has to be between 75% and 87.5% for 3-yearly DNA stool testing to be on the frontier with the base-case cost of $350.

Table 11 contains the results of the threshold analysis from a modified societal perspective. From this perspective the threshold costs that result in the DNA stool test reaching the efficient frontier are $105–$151 for the 5-yearly DNA stool test strategy and $90–$133 for 3-year DNA stool testing (version 1.1). These thresholds costs are considerably higher than those from the payer perspective. The higher frequency of Hemoccult II and Hemoccult SENSA scenarios results in considerably higher additional time costs than with DNA stool screening, allowing for higher per-test costs for the DNA stool test. The total threshold costs include co-payments and patient time costs. To obtain CMS reimbursement rates co-payments and patient time costs should be subtracted from the total threshold costs. Assuming no co-payments and patient time costs of $17 yields CMS reimbursement rates of $88–$134 for 5-yearly DNA stool testing and $73–$116 for 3-yearly DNA stool testing.

We also looked at the potential effect of lower Hemoccult II sensitivity on the threshold costs for the DNA stool test. For the SimCRC model, this would not influence the threshold costs, because Hemoccult II is not on the efficient frontier. According to the MISCAN model, Hemoccult II is one of the efficient strategies and on the frontier. With a 13% sensitivity for CRC, the most that could happen is that Hemoccult II would no longer be on the frontier. This would change threshold cost to $17 for version 1.0 irrespective of 3 or 5-year interval. For version 1.1 the threshold costs would become $69 for DNA stool screening every 5 years and $60 for every 3 years. So for both models the threshold costs did not change dramatically.

All analyses were conducted for the Medicare population aged 65 years and older and we assumed no prior screening in this group. To assess the effect of this assumption, we evaluated the cost-effectiveness of the 17 screening strategies for a cohort of 50-year-olds, with screening starting at age 50. Results are presented in Appendix 6. The DNA stool tests remained the most expensive of the test considered. In the SimCRC analysis, DNA stool testing every 3 years with version 1.1 continued to be the only DNA stool test that provided more life-years gained than annual screening with Hemoccult II; in the MISCAN analysis, all four DNA stool tests evaluated were less effective than annual Hemoccult II. At a per-test cost of $350, both models found the DNA stool test strategies to be the most expensive of the strategies considered; the per-test cost would have to fall to $27–$52 to be on the efficient frontier.

Finally, the threshold costs of DNA stool testing (version 1.1) every 2 years were estimated to be $44 for MISCAN and $62 for SimCRC.

Table 7A Undiscounted costs (by type), number of life-years gained, and number of cases of CRC per 1,000 65-year-olds, by screening scenario – MISCAN

| Costs ($) | | | | | | | Outcomes
Scenario | Screening | Follow-Up | Polyp Resection | Surveillance | Complications | CRC Treatment | Total Costs | LYG | SymDx CRC | ScnDx CRC
No Screening | $0 | $0 | $0 | $0 | $0 | $4,030,647 | $4,030,647 | 0 | 57 | 0
sDNA-3 (v1.0) | $1,419,427 | $181,848 | $72,878 | $350,014 | $13,292 | $3,159,608 | $5,197,067 | 92 | 25 | 18
sDNA-3 (v1.1) | $1,362,699 | $199,796 | $91,934 | $443,832 | $16,086 | $2,784,833 | $4,899,180 | 120 | 18 | 19
sDNA-5 (v1.0) | $1,013,408 | $136,033 | $56,152 | $262,042 | $9,949 | $3,372,775 | $4,850,360 | 73 | 31 | 15
sDNA-5 (v1.1) | $977,050 | $163,499 | $78,796 | $368,694 | $13,301 | $2,988,979 | $4,590,318 | 104 | 22 | 18
HII | $45,567 | $207,506 | $87,025 | $418,971 | $15,657 | $2,925,082 | $3,699,806 | 116 | 18 | 21
HS | $31,752 | $370,324 | $125,518 | $693,308 | $26,582 | $2,500,216 | $3,747,699 | 142 | 11 | 20
FIT | $178,070 | $318,965 | $116,195 | $614,451 | $23,328 | $2,571,850 | $3,822,859 | 140 | 12 | 21
SIGB | $516,675 | $193,588 | $115,573 | $545,369 | $19,109 | $2,415,712 | $3,806,025 | 131 | 16 | 14
SIG | $378,688 | $268,724 | $124,836 | $634,022 | $23,148 | $2,372,366 | $3,801,783 | 135 | 15 | 15
HII + SIGB | $471,001 | $279,352 | $130,885 | $665,263 | $24,149 | $2,102,977 | $3,673,628 | 148 | 11 | 17
HII + SIG | $355,287 | $332,971 | $136,711 | $730,017 | $26,785 | $2,277,709 | $3,859,480 | 149 | 11 | 17
HS + SIGB | $344,189 | $398,645 | $145,063 | $819,206 | $30,828 | $2,022,441 | $3,760,373 | 153 | 10 | 17
HS + SIG | $262,943 | $422,609 | $147,761 | $854,744 | $32,085 | $2,211,166 | $3,931,308 | 153 | 10 | 17
FIT + SIGB | $507,503 | $356,940 | $140,680 | $765,510 | $28,498 | $2,234,254 | $4,033,384 | 153 | 10 | 18
FIT + SIG | $402,034 | $391,163 | $144,354 | $811,076 | $30,463 | $2,221,929 | $4,001,019 | 153 | 10 | 17
COL | $776,378 | $0 | $152,503 | $677,095 | $36,325 | $2,198,557 | $3,840,859 | 151 | 12 | 15

LYG = life-years gained compared with no screening

SymDx CRC = symptom-detected colorectal cancer

ScnDx CRC = screen-detected colorectal cancer

Table 7B Undiscounted costs (by type), number of life-years gained, and number of cases of CRC per 1,000 65-year-olds, by screening scenario – SimCRC

| Costs ($) | | | | | | | Outcomes
Scenario | Screening | Follow-Up | Polyp Resection | Surveillance | Complications | CRC Treatment | Total Costs | LYG | SymDx CRC | ScnDx CRC
No Screening | $0 | $0 | $0 | $0 | $0 | $3,406,503 | $3,406,503 | 0 | 57 | 0
sDNA-3 (v1.0) | $1,468,511 | $172,574 | $55,388 | $210,571 | $10,279 | $2,595,692 | $4,513,016 | 83 | 20 | 20
sDNA-3 (v1.1) | $1,448,098 | $178,178 | $65,416 | $265,912 | $11,634 | $1,931,696 | $3,900,933 | 122 | 12 | 18
sDNA-5 (v1.0) | $1,046,873 | $127,259 | $42,469 | $157,897 | $7,799 | $2,813,180 | $4,195,476 | 58 | 27 | 18
sDNA-5 (v1.1) | $1,031,352 | $139,686 | $53,868 | $214,483 | $9,291 | $2,201,285 | $3,649,965 | 99 | 17 | 18
HII | $75,126 | $190,907 | $63,945 | $249,401 | $11,699 | $2,233,227 | $2,824,305 | 111 | 13 | 22
HS | $122,603 | $363,995 | $101,136 | $407,203 | $21,525 | $1,648,494 | $2,664,956 | 143 | 6 | 18
FIT | $250,342 | $308,947 | $91,616 | $368,816 | $18,539 | $1,726,963 | $2,765,224 | 141 | 7 | 19
SIGB | $549,359 | $130,176 | $68,055 | $297,321 | $10,841 | $1,791,959 | $2,847,711 | 111 | 18 | 10
SIG | $457,544 | $220,570 | $82,655 | $351,252 | $15,398 | $1,686,085 | $2,813,504 | 118 | 15 | 11
HII + SIGB | $612,219 | $253,306 | $82,674 | $238,708 | $13,117 | $1,465,526 | $2,665,551 | 148 | 6 | 15
HII + SIG | $533,441 | $334,296 | $89,970 | $254,103 | $15,600 | $1,412,301 | $2,639,711 | 150 | 6 | 15
HS + SIGB | $501,725 | $392,829 | $110,795 | $415,367 | $22,411 | $1,263,911 | $2,707,038 | 158 | 4 | 14
HS + SIG | $447,431 | $447,502 | $114,907 | $429,300 | $24,196 | $1,239,606 | $2,702,942 | 159 | 4 | 14
FIT + SIGB | $701,117 | $345,956 | $102,925 | $364,191 | $19,389 | $1,289,776 | $2,823,355 | 157 | 5 | 14
FIT + SIG | $643,031 | $409,891 | $107,860 | $377,288 | $21,379 | $1,261,588 | $2,821,036 | 158 | 4 | 14
COL | $793,467 | $0 | $138,695 | $597,506 | $34,731 | $1,113,881 | $2,678,281 | 159 | 4 | 12

LYG = life-years gained compared with no screening

SymDx CRC = symptom-detected colorectal cancer

ScnDx CRC = screen-detected colorectal cancer

Table 8 Discounted costs and life-years gained per 1,000 65-year-olds without CRC screening and with 16 CRC screening strategies and associated incremental cost-effectiveness ratios (ICERs)

| MISCAN | | | SimCRC
Strategy | Discounted costs | Discounted life- years gained | ICER | Discounted costs | Discounted life- years gained | ICER
No Screening | $2,714,556 | 0 | d | $2,295,628 | 0 | d
sDNA-3 (v1.0) | $3,860,227 | 51.4 | d | $3,473,214 | 42.2 | d
sDNA-3 (v1.1) | $3,673,499 | 68.0 | d | $3,081,338 | 64.2 | d
sDNA-5 (v1.0) | $3,533,981 | 40.9 | d | $3,147,621 | 28.6 | d
sDNA-5 (v1.1) | $3,382,910 | 58.8 | d | $2,814,315 | 51.4 | d
HII | $2,630,626 | 65.1 | --- | $2,121,988 | 57.9 | d
HS | $2,715,327 | 80.4 | $5,600 | $2,078,632 | 76.1 | ---
FIT | $2,776,790 | 79.4 | d | $2,155,730 | 75.0 | d
SIGB | $2,823,196 | 74.3 | d | $2,189,080 | 58.7 | d
SIG | $2,810,490 | 76.2 | d | $2,176,765 | 62.4 | d
HII + SIGB | $2,793,754 | 84.1 | $20,800 | $2,127,263 | 79.0 | d
HII + SIG | $2,840,538 | 84.6 | d | $2,113,618 | 80.2 | $8,600
HS + SIGB | $2,863,769 | 87.1 | $23,900 | $2,187,768 | 84.7 | d
HS + SIG | $2,909,359 | 87.1 | d | $2,187,042 | 85.2 | $14,600
FIT + SIGB | $3,025,571 | 87.1 | d | $2,282,357 | 84.6 | d
FIT + SIG | $2,992,773 | 87.2 | $924,800 | $2,283,025 | 85.1 | d
COL | $2,906,064 | 86.2 | d | $2,199,809 | 85.5 | $40,200

--- indicates default strategy (i.e., the least costly and least effective non-dominated strategy)

d = dominated

Figure 2 Panel A Discounted costs and discounted life-years gained per 1,000 65-year-olds for 16 CRC screening strategies and the efficient frontier connecting the efficient strategies - MISCAN

Costs Without Screening

Figure 2 Panel B Discounted costs and discounted life-years gained per 1,000 65-year-olds for 16 CRC screening strategies and the efficient frontier connecting the efficient strategies – SimCRC

Costs Without Screening

Table 9 Threshold analysis on DNA stool test characteristics: unit costs for DNA stool test resulting in equal cost-effectiveness (ACER and ICER) compared to current recommended CRC screening strategies for different combinations of test sensitivity and specificity^*^

| Base cases | | Sensitivity analysis of hypothetical test characteristics (sensitivity + specificity) †
| sDNA (v1.0) | sDNA (v1.1) | sDNA (v2.0) | sDNA (v1.1) + 10% | sDNA (v1.1) + 25% | sDNA (v1.1) + 50% | sDNA (v1.1) + 75% | sDNA (v1.1) + 100% (=perfect)
5-yearly DNA stool testing
On efficient frontier | NT, NT | 34^‡^, 51^‡^ | 2, 31^‡^ | 85, 85^‡^ | 117^‡^, 128 | 163, 187 | 215, 250^§^ | 329^§^, 364^§^
Cost-neutral vs. no screening | 7, 16 | 69, 139 | 32, 131 | 115, 177 | 138, 214 | 154, 251 | 159, 273 | 163, 288
Equal to highest ACER | 5, 76 | 136, 157 | 148, 126 | 173, 217 | 209, 259 | 245, 295 | 267, 312 | 281, 324
3-yearly DNA stool testing
On efficient frontier | NT, NT | 40, 60^‡^ | 17, 41^‡^ | 79^‡^, 87 | 102, 118 | 140, 167 | 179^§^, 247^§^ | 237^§^, 302^§^
Cost-neutral vs. no screening | 13, 17 | 60, 123 | 23, 118 | 96, 146 | 108, 167 | 117, 188 | 121, 200 | 123, 207
Equal to highest ACER | 11, 70 | 120, 133 | 125, 114 | 143, 176 | 163, 202 | 183, 223 | 195, 234 | 202, 241

ACER = average cost-effectiveness ratio compared with no screening (calculated using discounted costs and life-years gained)

ICER = incremental cost-effectiveness ratio (calculated using discounted costs and life-years gained)

NT = no threshold found (i.e., negative DNA stool test cost)

* MISCAN values in plain text; SimCRC values in italics

† See Table 6 for the sensitivity and specificity estimates used in these scenarios

‡ DNA stool test strategy is on the frontier as the least effective and least costly non-dominated strategy if the cost is at most this amount

§ DNA stool test strategy is on the frontier with ICER of $100,000 if the cost is at least this amount

Table 10 Threshold analysis on DNA stool test adherence: unit costs for DNA stool test resulting in equal cost-effectiveness (ACER and ICER) compared to current recommended CRC screening strategies for different levels of adherence with DNA stool screening^*^

sDNA (v1.1) | Base cases | Sensitivity Analysis on sDNA adherence^†^
| Adherence 50% for all strategies | sDNA adherence 55% | sDNA adherence 62.5% | sDNA adherence 75% | sDNA adherence 87.5% | sDNA adherence 100%
5-yearly DNA stool testing
On efficient frontier | 34^‡^, 51^‡^ | 37^‡^, 59^‡^ | 56, 68^‡^ | 83, 141^§^ | 221^§^, 483^§^ | 472^§^, 740^§^
Cost-neutral vs. no screening | 69, 139 | 69, 139 | 69, 139 | 69, 139 | 69, 139 | 69, 139
Equal to highest ACER | 136, 157 | 136, 157 | 136, 157 | 136, 157 | 136, 157 | 136, 157
3-yearly DNA stool testing
On efficient frontier | 40, 60^‡^ | 52, 66^‡^ | 81, 84 | 314^§^, 391^§^ | 552^§^, 637^§^ | 730^§^, 822^§^
Cost-neutral vs. no screening | 60, 123 | 60, 123 | 60, 123 | 60, 123 | 60, 123 | 60, 123
Equal to highest ACER | 120, 133 | 120, 133 | 120, 133 | 120, 133 | 120, 133 | 120, 133

ACER = average cost-effectiveness ratio compared with no screening (calculated using discounted costs and life-years gained)

ICER = incremental cost-effectiveness ratio (calculated using discounted costs and life-years gained)

* MISCAN values in plain text; SimCRC values in italics

† Strategies other than DNA stool test remain at 50% adherence

‡ DNA stool test strategy is on the frontier as the least effective and least costly non-dominated strategy if the cost is at most this amount

§ DNA stool test strategy is on the frontier with ICER of $100,000 if the cost is at least this amount

Table 11 Threshold analysis from modified societal perspective: unit costs for DNA stool test resulting in equal cost-effectiveness (ACER and ICER) compared to current recommended CRC screening strategies for modified societal perspective

| Total Threshold costs (includes co-payments and patient time costs) | | | CMS reimbursement rates (excludes co- payments and patient time costs)
| sDNA (v1.0) | sDNA (v1.1) | sDNA (v2.0) | sDNA (v1.0) | sDNA (v1.1) | sDNA (v2.0)
5-year DNA stool testing
On efficient frontier | NT, 54^‡^ | 105^‡^, 151 | 50, 110 | NT, 37 | 88, 134 | 33, 93
Cost-neutral vs. no screening | NT, 25 | 97, 151 | 36, 110 | NT, 8 | 80, 134 | 19, 93
Equal to highest ACER | 31, 131 | 239, 254 | 232, 243 | 14, 114 | 222, 237 | 215, 226
3-year DNA stool testing
On efficient frontier | NT, 35^‡^ | 90, 133 | 56, 97 | NT, 18 | 73, 116 | 39, 80
Cost-neutral vs. no screening | NT, 23 | 83, 133 | 21, 97 | NT, 6 | 66, 116 | 4, 80
Equal to highest ACER | 44, 118 | 212, 213 | 201, 208 | 27, 101 | 195, 196 | 191, 184

ACER = average cost-effectiveness ratio compared with no screening (calculated using discounted costs and life-years gained)

ICER = incremental cost-effectiveness ratio (calculated using discounted costs and life-years gained)

NT = no threshold found (i.e., negative DNA stool test cost)

* MISCAN values in plain text; SimCRC values in italics

‡ DNA stool test strategy is on the frontier as the least effective and least costly non-dominated strategy if the cost is at most this amount