# LITERATURE REVIEW FOR DNA STOOL TEST CHARACTERISTICS

The literature review for the DNA stool test was based on a PubMed search through January 2007 using the following search terms: “(neoplasm* OR cancer) AND (fecal DNA OR stool DNA OR (stool AND DNA))”. The same search terms were used in the 2006 Technology Evaluation Center (TEC) report. We assumed that the TEC systematic review of the literature (Technology Evaluation Center, 2006) represented the best evidence at the time and we were primarily interested in identifying the more recent studies. The main additions include an abstract by Ahlqhist (2007) and the publication of the study by Itzkowitz and colleagues (2007) that provides more detailed information than previously available in abstract form. In order to incorporate the most recent information on this emerging technology, we included abstracts when applicable. All studies of DNA stool test characteristics were for a one-time test. No studies to date evaluate repeat screening with a DNA stool test. Therefore, we do not have information on the degree to which false-negative test results are random (i.e., the adenoma or cancer expresses one of the mutations that the test identifies but the test is negative due to random reasons) or systematic (i.e., the adenoma or cancer does not express any of the mutations that the test identifies so the test will continue to be falsely negative on repeat screenings). A summary of the papers is given in Appendix 1.

## Version 1.0

EXACT Science developed a test that detects tumor markers in stool. Initial studies of the DNA stool test were performed using a pre-commercial prototype version of this test, which we refer to in this report as version 1.0. Imperiale (2004) conducted a multi-center (81 sites) colonoscopy study in an average-risk asymptomatic population age 50 or older (75% of subjects age 65 or older). Subjects were also given the Hemoccult II guaiac stool test (three cards) and the pre-commercial version of the PreGen-Plus test (i.e., version 1.0) prior to the colonoscopy. The Hemoccult II test was developed in accordance with the daily clinical practice of each site, and the stool DNA stool test was processed centrally by EXACT. The primary clinical findings were minor polyps (17% of subjects had tubular adenomas and 14% had hyperplastic polyps). Of 4404 subjects undergoing colonoscopy, 426 (10%) had one or more advanced adenomas (adenoma ≥1 cm or adenoma < 1 cm with villous histology or high-grade dysplasia) and 31 had CRC (0.7%). Of the 426 patients with advanced adenomas, 139 (33%) contained villous histology and 41 (10%) showed high-grade dysplasia. The sensitivity of the DNA stool test version 1.0 for CRC was 52%; 23 (72%) of the cases detected by the DNA stool test were early stage (TNM stage I or II). This sensitivity estimate was lower than that reported in clinical non-screening studies among subjects with advanced symptomatic cases, but was four times higher than the sensitivity of the Hemoccult II for CRC (13%) (p=0.003). The sensitivity of Hemoccult II for detecting CRC was much lower in the Imperiale study than the 40% that has been in an overview of studies (Pignone 2002b). The specificity of the DNA stool test version 1.0 was comparable with that of Hemoccult II. Of particular value in the Imperiale study was the reporting of sensitivity of the DNA stool test version 1.0 and of Hemoccult II by size of adenoma, stage of CRC, and histology. The DNA stool test version 1.0 had higher sensitivity for the adenomas with high-grade dysplasia than for large adenomas without high grade dysplasia or smaller adenomas.

A study with similar design to Imperiale’s study is underway by Ahlquist (U01 CA 89389). This study also used the pre-commercial version of the DNA stool test (i.e., version 1.0) and had planned to accrue 4000 patients by 2006. Interim results among 2507 patients published in abstract form reported that the sensitivity for screening for advanced neoplasia (CRC, high-grade dysplasia, villous component, or adenoma of size ≥1.0 cm) was 20% for the DNA stool test compared with 12% for Hemoccult II (p=0.03), but there was no difference between the detection of CRC or high-grade dysplasia between the tests (sensitivity of 35% for DNA stool test and 39% for Hemoccult II, p=0.76) (Ahlquist 2005). In this report we use the sensitivity and specificity estimates reported by Imperiale (2004) in our analysis of the DNA stool test version 1.0.

### Version 1.1 (PreGen-Plus)

The original version of the DNA stool test (version 1.0) used bead-based technology to extract DNA from stool. The currently-available version 1.1 (PreGen-Plus) includes improvements by LabCorp as described by Whitney (2004) and Olson (2005), including the use of a new gel-based DNA capture approach to enhance yield of human sequence specific DNA from stool. This new procedure was assessed by Whitney (2004) on 86 subjects with CRC and 100 subjects found to have no cancers at colonoscopy. Archival stool samples from these patients had been frozen within 24 to 72 hours after collection. Sensitivity for CRC (70%) and specificity (96%) were higher in the Whitney study than in the Imperiale study. We used the sensitivity for CRC and specificity reported by Whitney for our analysis of the DNA stool test version 1.1.

Although Whitney (2004) included a control group of subjects with no cancer detected on colonoscopy, no information was given on the prevalence of adenomas among these subjects. Accordingly, no estimates were provided for the sensitivity of the DNA stool test for adenomas by size. We used data from studies by Tagore (2003) and Syngal (2006) on the sensitivity of the DNA stool test version 1.0 for large adenomas (≥ 1.0 cm). In the absence of any other data on the sensitivity of the DNA stool test version 1.1 for adenomas 0.6–0.9 cm, we assumed that the sensitivity for medium (0.6–0.9 cm) adenomas was unchanged from those reported by Imperiale (2004). We further assumed that adenomas of size <0.5 cm were not detectable by the DNA stool test but could be detected as false positive results (1-specificity) of DNA stool testing.

Ahlquist (2007) presented results on a DNA stool test incorporating an improved marker panel and DNA capture method and compared the test characteristics with those of Hemoccult II and Hemoccult SENSA^®^. The version of the test was not explicitly stated, but given the inclusion of an improved marker panel and a new marker, vimentin, it is likely a combination of version 1.1. (improved markers and stool management) and version 2.0 (inclusion of vimentin marker). The blinded multi-center study (NCI-CA 89389) had 4010 asymptomatic average-risk adults with colonoscopy. DNA stool testing was conducted on 218 patients from subsets of those with ‘screen-relevant neoplasia’ (143) and the colonoscopic normal patients (75). Sensitivity for CRC was 58% and specificity 84%. Sensitivity for adenomas ≥1.0 cm was 45%.

## Version 2.0

The 52% sensitivity of the DNA stool test for CRC reported by Imperiale (2004) in the study of colonoscopy in an asymptomatic average-risk population was lower than that obtained from studies using clinically detected cancers (Ahlquist (91%) (2000); Tagore (63%) (2003), Calistri (62%) (2003), Brand (69%) (2004), or Syngal (54%) (2006)). Further assessment of the prototype DNA stool test version 1.0 used in the Imperiale study found that the lower-than-expected sensitivity was due in part to an unexpectedly low rate of positivity for the DIA® component. This issue was also seen in the contemporaneous Ahlquist study (NCI-CA 89389) where specimens were handled similarly. DNA degradation had occurred during transit of specimens to the laboratory even though the protocol was for samples to be immediately chilled and sent by express courier for rapid delivery. A DNA-stabilizing buffer was developed to be applied to the stool immediately on defecation (Itzkowitz 2007) to prevent DNA degradation for several days and enhance the performance. Also a methylation-specific PCR assay was developed to detect aberrant vimentin methylation, which has been associated with CRCs. Itzkowitz and colleagues conducted a clinical trial in 7 centers of the improved gel-based capture (used in version 1.1), the DNA stabilizing buffer, and vimentin markers. Subjects aged 50–80 who were having colonoscopy in general practice were eligible for the study. Those found to have CRC or no polyps were asked to give a stool sample for testing 6–14 days after the colonoscopy was performed and in the case of those with CRC, prior to surgery for CRC. There were 40 patients with CRC (average age 66 and 50% with early-stage CRC) and 122 no-polyp patients (average age 59) enrolled in this study. With respect to the effect of using post-colonoscopy stools versus pre-colonoscopy stools, a study of post-colonoscopy stool samples from patients with CRC conducted during the same time period as the Imperiale study found that the sensitivity estimated using the post-colonoscopy stool samples (43%) was lower than for that from pre-colonoscopy stool samples (52%) for Imperiale’s study suggesting that use of post-colonoscopy stools may underestimate the DNA stool test performance.

With the DNA stabilization buffer and a gel-based DNA purification method, the sensitivity for CRC was 72% for the DNA stool test version 2.0. The sensitivity of the DIA component with the gel-based purification increased from 3% to 65%. Specificity was 89%, lower than the 95% specificity of version 1.0. Vimentin alone had a sensitivity of 73% and specificity of 87%. The least complex assay consisting of two markers—aberrant hypermethylation of vimentin and a two-site DIA (DIA-DY)—had a maximum sensitivity of 88% with a specificity of 82%. These estimates of sensitivity and specificity were from training set analyses designed to determine optimal markers and cutoff values and represent a reduced set of markers from those tested in the Imperiale study. A validation set analysis in an unselected screening population is needed for confirmation of these results. However these initial observations suggest that a test with the two markers (vimentin+DY) could provide sensitivity of 88% and might be the basis for an assay kit that could be managed by many clinical laboratories. Given the post-colonoscopy collection of stool, the adenoma was not studied with the newer markers. The authors noted the need to assess this version for detection of adenomas. Version 2.0 is not yet commercially available. We do consider an optimistic version 2.0 result for a sensitivity analysis on test performance. We use the slightly improved estimates of 90% sensitivity and 85% for specificity as a hypothetical best case for version 2.0. As Itzkowitz notes, it is not known how the new version 2.0 assay will perform in a screening study where most cancers are at an earlier stage where sensitivity tends to be lower and how it will perform in adenoma detection. Also of interest is further confirmation of the specificity of the version 2.0, which was lower than for earlier versions and could mean that this version of the DNA stool test is not necessarily specific for CRC neoplasia. The DNA stool test is continuing to evolve. Version 2.0 is included in the analysis as a sensitivity analysis.