# DISCUSSION

## Summary of Results

We conducted a cost-effectiveness analysis of the DNA stool test in comparison with the currently recommended CRC screening tests of colonoscopy, flexible sigmoidoscopy, and FOBT (guaiac Hemoccult II and SENSA, and FIT) in response to a request by CMS. The analysis is based on a cohort of previously unscreened 65-year-old individuals followed over their lifetimes and is conducted from both the CMS payer perspective and a modified societal perspective. We evaluated two versions of the DNA stool test—version 1.0 (a pre-commercial version of PreGen-Plus) and version 1.1 (currently commercially available through LabCorp and marketed as PreGen-Plus)—and screening intervals of 3 and 5 years. For three of the four DNA stool testing strategies evaluated, the screening benefit, measured in terms of life-years gained compared with no screening, was lower than that of annual Hemoccult II testing; the number of life-years gained was higher than that of annual Hemoccult II testing if the DNA stool test is performed every 3 years with version 1.1. However, the overall costs of all four DNA stool testing strategies were higher than all of the other screening strategies considered. The DNA stool test strategies considered were all more costly and less effective that an alternative strategy (i.e., strongly dominated) or a combination of other strategies (i.e., weakly dominated).

The fact that DNA stool testing, based on evidence available to date, was not cost-effective when compared with the other CRC screening tests had been anticipated, given that the DNA stool test was not more sensitive or specific than Hemoccult SENSA and yet almost 80 times as expensive. Consequently the aim of this analysis was also to explore the conditions under which the DNA stool test (or for that matter any other new test) could compete with the existing screening tests. We therefore conducted threshold analyses to determine what a DNA stool test would have to cost in order for one of the DNA stool test strategies to lie on the efficient frontier (i.e., be a non-dominated strategy). Our results indicate that the version 1.0 strategy could never be a cost-effective alternative compared to the current recommended screening strategies (i.e., it remains more costly and less effective than other strategies even if the test is free). Screening with the PreGen-Plus (version 1.1) test would lie on the efficient frontier at a cost of $34–$51 for a 5-yearly DNA stool testing and $40–60 for a 3-yearly DNA stool testing.

We also conducted sensitivity analyses to assess how potential changes in the sensitivity and specificity estimates, especially for adenomas, would affect the threshold analysis on the DNA stool test cost. We included a third sensitivity analysis for a hypothetical version for the DNA stool test (version 2.0) with enhanced sensitivity and specificity over that of the latest reported development for the test. Even for the enhanced test the threshold value for the DNA stool test was $17–$41 with an interval of three years and $2–$31 with a 5-year interval. Version 2.0 actually has lower threshold costs than version 1.1 because it has a lower specificity (even though the sensitivity is higher). With lower specificity, more people are referred to colonoscopy and colonoscopy-related costs become a larger portion of total costs. Hence, there are fewer screening tests with which to lower the total costs; hence lower costs per DNA stool test are required. We further allowed the sensitivity and specificity of the DNA stool test to range upwards from the version 1.1 estimates to a perfect test. The sensitivity and specificity of the DNA stool test were allowed to increase to even that of a perfect test and the threshold cost for the DNA test remained below or close to $350.

We conducted a second sensitivity analyses to address the question of whether with increasing adherence the DNA stool test would be on the efficiency frontier. For this analysis we assumed that adherence was 50% for the currently recommend tests and that there was increased adherence with the DNA stool test strategies among unscreened individuals. If the DNA stool test version 1.1 was able to increase screening adherence by 50% to 75% adherence, the threshold costs could increase to $83–$141 at 5-yearly intervals of testing and to $314–$391 at 3-yearly intervals of testing. With perfect adherence per-test the costs could be $472–$740 at 5-yearly intervals and $730–$822 at 3-yearly intervals, assuming an adherence of 50% for all other tests.

We assumed that all in the cohort of 65-year-old individuals were previously unscreened. In reality, many subjects entering the Medicare program will have had screening before age 65. Of those with prior screening, only those without adenomas detected are still eligible for average risk screening. Adenoma patients should undergo more frequent surveillance with colonoscopy (Winawer 2006) than those with no neoplasia. This means that on average the eligible population for average-risk screening entering Medicare will be at lower risk than an unscreened population. This means that we have overestimated the life-years gained from screening. However, this holds for all tests and strategies and is therefore not expected to significantly influence our results, because the relative performance of one test over the other remains the same. We assessed the potential effect of the assumption of an unscreened 65-year old population, by determining threshold costs for DNA stool screening when screening a 50-year old cohort from age 50 onwards. This did not change the results significantly.

Analyses conducted from a modified societal perspective yielded threshold per-test costs that were approximately 2 to 3 times greater than the analyses from the CMS perspective.

## Cost-effectiveness of Currently Recommended Test Strategies

An important finding from our analysis is that the currently recommended CRC screening tests provide good value for the resources spent. Hemoccult II, the test proven in randomized controlled trials to reduce CRC mortality by 15–33%, with a $4.54 CMS reimbursement, is cost saving relative to no screening. Other FOBTs as well as flexible sigmoidoscopy and colonoscopy provided additional life-years gained over Hemoccult II, often with reasonable costs. Our favorable cost-effectiveness result for the CRC screening strategies is likely due to the increasing costs of CRC and the costs of the screening tests not increasing at the same rate or even lower than previously reported. In this analysis all the costs come from the same source: Medicare reimbursement. The costs for treating CRC stage III and IV and incurable CRC have been increasing since the introduction of newer therapies. The reason that the SimCRC model found more cost-saving strategies is likely due to the fact that it finds a great reduction in cancer incidence with CRC screening because of its longer dwell time. Using the SimCRC model we found that if the total discounted treatment costs decrease by about 10%, then only Hemoccult II, Hemoccult SENSA, and Hemoccult II with sigmoidoscopy with biopsy are cost-saving. If the treatment costs decrease by 12% only Hemoccult II and Hemoccult SENSA are cost-saving, and if they decrease by 22% none of the strategies is cost-saving.

## Evaluation of New Screening Tests in Relationship to Current Recommendations

CRC screening guidelines from the Multi-Society Task Force were published in 1997 for currently available tests but the authors also considered how to evaluate new screening tests as well. The guidelines state that a newer test could be substituted for a currently recommended test (or added to the recommendations) if evidence were available to demonstrate that the new test had: (1) a comparable performance for sensitivity and specificity in detecting cancer or adenomatous polyps at comparable stages, (2) was equally acceptable to patients, and (3) had comparable or lower complication rates and costs (Winawer 1997). We address each of these issues below.

### Strength of the evidence for the DNA stool test as a screening test

The PreGen-Plus (version 1.1) test, as reported by Whitney, achieves a sensitivity for CRC as high as that reported for FIT and Hemoccult SENSA, with a higher sensitivity for large adenomas than with FIT or Hemoccult SENSA and with a specificity as high as FIT. However these estimates from the Whitney study were based on archived samples rather than a clinical trial of screening. The subsequent clinical study by Itzkowitz (2007) using the version 1.1 assay obtained a sensitivity of 72.5%, comparable to that of Whitney but had considerably lower specificity (89%) compared to Whitney (96%). Consequently the PreGen-Plus test has better sensitivity for CRC compared with Hemoccult II, more comparable sensitivity for CRC as FIT and Hemoccult SENSA, better sensitivity than Hemoccult II, SENSA and FIT for large adenomas (≥1.0 cm) and comparable or lower specificity as FIT and Hemoccult SENSA. There are no direct data on the sensitivity of the DNA stool test version 1.1 for detecting adenomas of any size; there are only data using version 1.0. This lack of evidence is relevant because the ability of a screening test to prevent CRC is through the identification and removal of adenomas. In addition, information on programmatic use of stool DNA (i.e., repeated screening) is not available; all the reported studies have been based on results of a one-time test. Future studies are needed to assess repeat screenings and the impact of a programmatic utilization of DNA stool test.

### Acceptability to patients as a screening test

The currently recommended CRC screening tests all require considerably more patient involvement than screening tests for other diseases. The individual undergoing screening must complete a cleansing bowel prep for colonoscopy or flexible sigmoidoscopy, restrict their diet for Hemoccult II or colonoscopy, restrict NSAID use with Hemoccult II, have contact with the stool for any of the FOBTs, and go to a medical setting for an invasive procedure for colonoscopy or flexible sigmoidoscopy. Colonoscopy procedures have a small but real risk of perforations and due to sedation, require an escort to and from the procedure. The DNA stool test does not require a bowel prep or dietary restriction, and requires only limited contact with the stool (i.e., one sample, which can be shipped for processing from any location). The patient satisfaction evaluation by Schroy (2005) in the Imperiale study suggests that the DNA stool test is acceptable to patients who have already agreed to participate in a screening program. Schroy’s patient survey was also used in routine clinical practice. Eighteen percent of patients who completed a PreGen-Plus completed the survey and reported that the collection process was easy to perform and that they were likely to use the test again. A recent report by Schroy (2007) noted that ambulatory care patients without prior endoscopy CRC or stool DNA screening, stated a preference for CRC screening as colonoscopy screening ( 51%), followed by stool DNA.

Consequently these studies demonstrate a stated willingness to use stool DNA screening in a percentage of patients interested in CRC screening. Our sensitivity analysis on adherence suggests that adherence would need to increase substantially for the DNA stool test to become cost-effective if the test cost was $350.

### Evidence on comparable or lower complication rates and costs

There are no known complications associated with the DNA stool test itself (aside from the potential of false positive or false negative results) and the test is therefore comparable to its stool-based alternatives. The proposed costs of $350 are considerably higher than those of the stool alternatives ($4.54 for Hemoccult II and SENSA, $22.22 for FIT). Our analysis shows that at these costs screening with the DNA stool test is not a cost-effective alternative to the current screening recommendations and therefore does not meet the guidelines for new screening tests.

## Consistency of Results from Two Microsimulation Models

All analyses were conducted by two separate microsimulation modeling groups of the NCI-sponsored modeling consortium, CISNET, using independently developed models but with common inputs. The comparability of the findings of the two modeling groups strengthens the credibility of our results and can be viewed as a sensitivity analysis of the underlying natural history assumptions. Both models have been calibrated to CRC incidence rates from a pre-screening era. Both models have been extensively validated against clinical trial data on Hemoccult II screening. The two models do differ in the dwell time from adenoma to clinically detectable CRC. MISCAN assumes a shorter dwell time and SimCRC a longer dwell time. Based on this difference in dwell time, the MISCAN model estimates fewer life-years saved from removing adenomas than SimCRC and MISCAN estimates a greater benefit for shorter rescreening intervals for adenoma-sensitive tests than does SimCRC. The fact that both models come to similar conclusions with respect to cost-effectiveness and threshold costs of DNA stool screening shows the robustness of the results for uncertainties in the duration of the adenoma-carcinoma sequence.

The distribution of dwell time from adenoma to carcinoma is not known with certainty. The uncertainty on dwell time affects the assessment of all the screening tests, including the DNA stool test. In particular if affects the tests with respect to detection of adenomas.

## Other Cost-effectiveness Analyses

There is one published cost-effectiveness analysis for the DNA stool test (Song, Fendrick, and Ladabaum 2004) and one published abstract (Parekh, Fendrick, and Ladabaum 2006). In the Parekh analysis a sensitivity of 52% for CRC and 18% for large polyps and a specificity of 94% were assumed, comparable to our version 1.0 test characteristics. Parekh (2006) found that at a DNA stool test cost of $300, 5-yearly stool DNA screening costs $18,000 per life-year gained. At a cost of $350 per test we found that screening with the DNA stool test version 1.0 from age 50 onwards, costs $25,000 per life-year gained in the MISCAN model and $21,000 in the SimCRC model, which are comparable. In a sensitivity analysis, Parekh also looked at test characteristics comparable to our version 2.0 test. With these test characteristics, he found costs of $13,000 per life-year gained. This number compares well with the MISCAN model at $13,000 per life-year gained and the SimCRC model at $6,000 per life-year gained. In the Song analysis, the authors assumed that the sensitivity of the DNA stool test was 65% for CRC and 40% for large polyps with a 95% specificity, comparable to our version 1.1 test characteristics. Song (2004) concluded that the DNA stool test was dominated by currently recommended CRC screening tests. If the DNA stool test was given at 2-year intervals at a cost of $195 then it would be comparable with colonoscopy (Song 2004). Their conclusion of dominance is corroborated by our findings. For comparison reasons we also looked at the threshold costs for stool DNA screening (version 1.1) if offered every 2 years. Our threshold costs of $44 for MISCAN and $62 for SimCRC are considerably lower than estimated by Song. There are two main reasons for this difference. In the first place, Song uses a different comparator for determining the threshold costs, namely colonoscopy. In our analysis 2-yearly DNA stool screening is not as effective as colonoscopy screening, although it is close. Secondly, costs for colonoscopy are considerably higher in the Song analysis compared to our colonoscopy cost estimates. If we would compare 2-yearly DNA stool version 1.1 testing with colonoscopy screening and assume double colonoscopy costs (approximately the difference between our and Song’s estimates), we would get threshold costs of $213 in both the MISCAN and SimCRC models, which is very comparable to the $195 estimate reported by Song.

## Limitations of Modeling Assumptions

The models simulate the progression from adenoma to CRC by increasing the size of the adenomas over time. Because adenoma size, villous component, and high-grade dysplasia are highly correlated (O’Brien, 1990), the size representation indirectly represents histology and high grade. However, neither model separately simulates the step from adenoma with low-grade dysplasia to an adenoma with high-grade dysplasia. If the advantage of the DNA stool test is detection of a smaller adenoma at the stage of high-grade dysplasia, then both models may be underestimating its effectiveness. We also did not allow for the de novo cancers (cancers that arise without a prior adenoma state). In the presence of de novo cancers the results of tests focusing on detecting only cancers becomes relatively more favorable. Because with Hemoccult II there is hardly any sensitivity for adenomas this tests becomes relatively more favorable compared to the other tests, including the DNA stool test. When Hemoccult II is the comparator (as with the MISCAN model), the threshold costs for the DNA stool test would become even lower. When Hemoccult SENSA is the comparator (as with the SimCRC model), the threshold costs would not change substantially. Lastly, we assumed that SEER incidence data prior to the time of active CRC screening in the US is a good representation of the cancer incidence expected today in an unscreened population. However, because there has been a small net improvement in CRC lifestyle risk factors for CRC over time (Knudsen 2004, 2005), estimates of CRC incidence may be overestimated. The impact of this overestimating CRC incidence is that all CRC screening benefits are also overestimated, though we would not expect significant differences in the relative benefit across strategies.

In the current analysis, we assumed conditional independence of repeat screenings. Consequently we assumed that there were no systematic false-negative results for adenomas and cancers. This is likely a reasonable assumption for FOBT and FIT testing because bleeding of a lesion is assumed to be a random event, so that if a test misses a lesion the first time, then it has approximately the same probability of catching a bleed on the next screen. This assumption may be less reasonable for endoscopy, as certain lesions may be more difficult to find (e.g., in a fold). However for the DNA stool test the lesion in question may have acquired a gene mutation not assessed by the DNA stool test, which means that if the DNA stool test was negative the first time because the gene mutation is not one assessed by the DNA stool test, it will be missed in all subsequent screens unless the neoplasm acquires and begins expressing a gene mutation assessed by the test. Consequently, our assumption of conditional independence does not hold for DNA stool test, and we may have overestimated the true benefit of DNA stool test. This implies that the true threshold costs for may be lower than estimated by these analyses in this report.

In this analysis, we included the current recommendations for average-risk CRC screening as the comparator strategies. We did not consider alternative screening intervals for the currently recommended screening tests. For example, we compared 3-yearly stool DNA testing with annual Hemoccult screening, although the performance characteristics of both tests are comparable. It is likely that the threshold cost of the DNA stool test version 1.1 would be considerably lower than the estimated $34–$60 if compared with 3-yearly or 5-yearly Hemoccult SENSA testing. We also made the assumptions that screening would stop at age 80 and that individuals would remain on a surveillance schedule for their lifetime, which may not be realistic assumptions for what occurs in practice.

In our sensitivity analysis of screening adherence we assumed that individuals would be either fully adherent with a screening strategy or never screened. This is an oversimplification of what occurs in practice, but is closer to reality than an assumption that individuals show up randomly to their scheduled screens. A recent study byCoups et al. (2007) of the NHIS data found that almost 40% of the US population aged 50 and older were adherent with CRC screening guidelines and only 13% were screened but not according to guidelines (the remaining group was never screened).

## Limitations of Cost Estimates

The costs of the screening tests, as well as the costs of complications associated with screening (primarily colonoscopy), were based on 2007 Medicare reimbursement rates. To the extent that these rates change differentially in the future (e.g., a decrease in the reimbursement rate for colonoscopy) our results will change. In the case of an anticipated decrease in colonoscopy reimbursement we would expect minimal changes to our conclusions about screening with the DNA stool test because the comparator used to calculate threshold test costs was FOBT and not colonoscopy.

Costs for CRC treatment were for the period 1998 to 2003. However there was minimal usage of the biologics in the period assessed so these new costs for biological are not a part of this study. We would expect that inclusion of these costs as later data become available would make the cost-effectiveness more favorable overall. CRC screening can have two potentially beneficial effects: 1) primary prevention of CRC through detection and removal of adenomas that might have eventually become cancer, and 2) early detection of CRC, when it is in a lower stage that is more amenable to treatment. In general, those strategies that are associated with a higher reduction in cancer incidence (i.e., act largely through primary prevention rather than early detection,) will have a greater net savings. Because we are comparing the DNA stool test strategies with FOBT strategies, and because both types of test strategies have comparable reductions in cancer incidence, we would not expect increases in CRC treatment cost to have a large impact on our estimates of threshold test costs (and we would anticipate that any change would be to decrease the threshold test cost values). There is also a difference in the years that we used to estimate survival (1996–1999). The impact of having cancer mortality estimates that are too high would be that the screening effectiveness would also be too high. For comparisons of tests that have similar cancer incidence reductions, as in the case of DNA stool test and FOBT, we expect the impact to be small but would favor the DNA stool test.

With the exception of the Warren, Klabunde, and Brown upcoming manuscript, there are few data specifically on colonoscopy complications in the Medicare population. For example, the Warren analysis reports hospitalization for dehydration following colonoscopy. This complication was not cited in the general population studies across ages. Complications rates are generally lower in organized screening programs, which often focus on the age group of 50 to 65 for CRC screening. Consequently a program to track complications in Medicare beneficiaries who receive CRC screening would be of value to assess the magnitude of risk for this age group.