# COST-EFFECTIVENESS ANALYSIS

## Overview

We used two existing microsimulation models validated against the best available data (Loeve 1999, 2000, Vogelaar 2006, Frazier 2000) to inform the CMS and AHRQ in assessing the effectiveness and cost-effectiveness of the DNA stool test, in comparison with the currently recommended CRC screening strategies. Although randomized controlled trials are the preferred method for establishing effectiveness of (screening) interventions, they are expensive and require long follow-up. Accordingly, well-validated microsimulation models may be used to estimate the required resources and expected benefits from different screening policies and inform decision making. The validity of the models is based on clinical incidence data before the introduction of screening (1975–1979 SEER data), more recent data on CRC survival (1996–1999 SEER data) and the size distribution of adenomas in colonoscopy and autopsy studies (Clark 1985, Blatt 1961, Arminski 1964, Vatn 1982, Jass 1992, Johannsen 1989, Bombi 1988, Williams 1982, Rickert 1979, Chapman 1963). The external validity has further been tested on the results of large (randomized) screening and surveillance studies, such as the Minnesota Colon Cancer Control Study (Mandel 1993), the CoCap sigmoidoscopy study (Doria-Rose 2004), and the National Polyp Study (Loeve 2000). The models also use common all-cause mortality estimates from the US life tables and colorectal cancer survival data from SEER (using data from 1996–1999). Finally, the models were able to explain observed incidence and mortality trends in the US when accounting for risk factor trends, screening practice and chemotherapy treatment (Vogelaar 2006, Knudsen 2004, 2005). Using two models (i.e., a comparative modeling approach) adds credibility to the modeling results and serves as a sensitivity analysis on the underlying structural assumptions of the models, particularly pertaining to the natural history of colorectal disease. Through the NCI CISNET consortium, standardized profiles of the each model’s structure and underlying assumptions are available at http://cisnet.cancer.gov/profiles/.

We used the MISCAN-COLON and SimCRC simulation models to calculate the lifetime costs (discounted and undiscounted) and life expectancy (discounted and undiscounted) for a cohort of 65-year-old individuals residing in the US (i.e., eligible for Medicare benefits) under 17 competing strategies, including no screening. The 16 CRC screening strategies vary by diagnostic test or combination of tests and screening interval. We conducted an incremental cost-effectiveness analysis from the perspective of CMS and discounted future costs and life years 3% annually (Gold 1996). Strategies that were more costly and less effective were ruled out by simple dominance. Strategies that were more costly and less effective than a combination of other strategies were ruled out by weak dominance. In this report, dominance refers to either simple or weak dominance. The relative performance of the remaining strategies was measured using the incremental cost-effectiveness ratio, defined as the additional cost of a specific strategy, divided by its additional clinical benefit, compared with the next least expensive strategy.

## Microsimulation Modeling

The MISCAN and SimCRC models simulate the life histories of a large population of individuals from birth to death. Each model has a natural history component that tracks the progression of underlying disease in the absence of screening. As each individual ages, there is a chance that an adenomatous polyp – a benign precursor lesion that may lead to CRC – develops.

One or more adenomas can occur in any individual and each can develop into preclinical CRC (Figure 1). The risk of developing an adenoma depends on age, sex, race, genetic and other propensity factors. The models track the location in the colon and the size of each adenoma, which influence disease progression and the chance of being found by screening.

Adenomas can progress from small (1–5 mm) to medium (6–9 mm) to large (10+ mm) size. Some adenomas eventually become malignant, transforming to stage I preclinical cancer. A preclinical cancer (i.e., not detected) has a chance of progressing through the stages (from stages I to IV) and may be detected by symptoms at any stage. We assume that adenomas are asymptomatic and can only be detected by a screening test.

To project the effectiveness of a screening strategy, the models incorporate a screening component together with the natural history model. The effectiveness of each screening test is modeled through each test’s ability to detect lesions (i.e., adenomas, preclinical cancer). Once screening is introduced, a simulated person who has an underlying adenoma or preclinical cancer has a chance of having it detected during a screening year depending on the sensitivity of the test for that lesion. For screened persons without an underlying lesion we apply the false-positive rate (1 – specificity) to determine whether or not that person will undergo an unnecessary follow-up examination. Hyperplastic polyps are not modeled explicitly but are reflected in the specificity of the test. In addition, a percentage of individuals with false-negative test results (i.e., adenoma or preclinical cancer present but not detected) will be referred to colonoscopy because of the detection of a hyperplastic polyp. Flexible sigmoidoscopy can only detect lesions located in the distal colon or rectum, while other tests have the ability to detect lesions in any part of the colorectal tract. Colonoscopy is associated with a small mortality risk due to the risk of perforation during the procedure.

The models include the possibility of multiple adenomas or preclinical cancers. A subject with multiple adenomas, especially multiple adenomas of a larger size, would be more likely on average to be detected by screening than a subject with a single small adenoma. Consequently multiplicity and size of the adenomas, or whether there is a preclinical cancer, are included in estimates of sensitivity and specificity.

Figure 1 Graphical representation of natural history of disease as modeled by MISCAN and SimCRC models. The opportunity to intervene in the natural history through screening is noted

Screening

### Key differences in model structures

Although the models are calibrated to the same data on adenoma prevalence and cancer incidence, the underlying distributions of dwell times (i.e., time from adenoma initiation to development of CRC) differ between the two models. A key assumption in the MISCAN model is that there are two types of adenomas: progressive adenomas (adenomas that eventually can become cancer) and non-progressive adenomas (adenomas that cannot become cancer). In the SimCRC model all adenomas have the ability to progress to cancer (although most will not during the lifespan of the individual). Although both models predict the same adenoma prevalence and CRC incidence, the difference in the adenoma growth assumptions results in different dwell time estimates between the MISCAN and SimCRC models. The dwell time is defined as the average time between adenoma formation and clinical cancer detection among all cases of cancer. In the MISCAN model adenomas and preclinical cancer have been present for 10 years on average before clinical diagnosis, while the estimate is approximately 22 years for SimCRC. Little is known about how fast this progression truly occurs. It is estimated that 30% to 50% of the population have one or more adenomas, but it is difficult to measure dwell time in a real population because, by definition, it is the period during which the condition is undiagnosed. As a result of the difference in dwell time, more life-years are gained from screening in the SimCRC model than in the MISCAN model. In the MISCAN model the additional benefit of increasing screening frequency will be greater than that in SimCRC. A summary of each model is in Appendix 2.

Another key difference between the models is the distribution of adenomas in the colorectal tract (see Appendix 3). In the MISCAN model, adenomas are assumed to have the same distribution as CRCs, while the SimCRC model is calibrated to the distribution of adenomas from autopsy studies. Approximately 30% of CRCs are located in the rectum, while data from autopsy studies suggest that 8–10% of adenomas are located in the rectum. As a result of this difference, the MISCAN model finds strategies involving sigmoidoscopy to be more effective than the SimCRC model, since a larger proportion of adenomas are within the reach of the sigmoidoscope.

As part of the CISNET consortium, we have thoroughly compared the models and found that differences in the average duration of the adenoma-carcinoma sequence explain most of the differences in model predictions.

## Study Population

We used the natural history models to estimate the distribution of underlying disease for the 65-year-old US population in 2005 in terms of the presence, location, size, and type (adenoma vs. preclinical cancer) of lesions (see Appendix 3 for comparison of natural history models). We conducted the analysis of the effect of different screening strategies among a 65-year-old cohort of individuals who have never been screened as our base case. However this cohort with no prior screening represents a higher-risk group than a cohort of previously-screened 65-year-old individuals. As a comparison, we conduct a sensitivity analysis for a 50-year-old cohort. The cohort was followed for life (ending at age 100). All inputs were standardized between the two models, including diagnostic performance criteria, costs, and screening and follow-up assumptions.

## Screening Strategies

In consultation with AHRQ and CMS, we compared the basic strategies of no screening, screening with FOBT every year, flexible sigmoidoscopy (SIG) every five years, combinations of FOBT and SIG, and colonoscopy every 10 years as recommended by the American Cancer Society (Smith 2006), the USPSTF (US Preventive Services Task Force 2002; Pignone 2002a) and the Multi-Society Task Force (Winawer 1997, 2003, 2006), along with screening with the DNA stool test (Table 1). Although barium enema is included in the screening recommendations, it was not considered in this analysis. We evaluated three FOBTs: Hemoccult II (HII), Hemoccult SENSA (HS) and immunochemical FOBT (FIT); two strategies for SIG (with and without biopsy); and two versions of the DNA stool test: the pre-commercial version 1.0 and the commercial version 1.1 (currently available and marketed as PreGen-Plus). The request for NCD asks for consideration of the DNA stool test every 5 years. We also evaluated a 3-year interval in these analyses. For the purposes of this report, we assumed that all individuals begin CRC screening at age 65 (i.e., the age at which Medicare eligibility begins) and end at age 80.

Table 1 Strategies considered in the cost-effectiveness analysis

| Test(s) | Abbreviation | Interval (test 1) | Interval (test 2) | Biopsy @SIG?
1 | None | | na | na | na
2 | DNA stool test (version 1.0) | sDNA-3 (v1.0) | 3 years | na | na
3 | DNA stool test (version 1.1) | sDNA-3 (v1.1) | 3 years | na | na
4 | DNA stool test (version 1.0) | sDNA-5 (v1.0) | 5 years | na | na
5 | DNA stool test (version 1.1) | sDNA-5 (v1.1) | 5 years | na | na
6 | Hemoccult II | HII | 1 year | na | na
7 | Hemoccult SENSA | HS | 1 year | na | na
8 | Fecal immunochemical test | FIT | 1 year | na | na
9 | Flexible sigmoidoscopy | SIGB | 5 years | na | yes
10 | Flexible sigmoidoscopy | SIG | 5 years | na | no
11 | Hemoccult II, SIG | HII+SIGB | 1 year | 5 years | yes
12 | Hemoccult II, SIG | HII+SIG | 1 year | 5 years | no
13 | Hemoccult SENSA, SIG | HS+SIGB | 1 year | 5 years | yes
14 | Hemoccult SENSA, SIG | HS+SIG | 1 year | 5 years | no
15 | FIT, SIG | FIT+SIGB | 1 year | 5 years | yes
16 | FIT, SIG | FIT+SIG | 1 year | 5 years | no
17 | Colonoscopy | COL | 10 years | na | na

### Follow-up, surveillance, and adherence

We assumed that any individual with a positive FOBT or a positive DNA stool test is referred for a follow-up colonoscopy. We evaluated two scenarios for flexible sigmoidoscopy: (1) all detected polyps are biopsied and any person with an adenomatous polyp is referred for a follow-up colonoscopy, and (2) all patients with detected polyps are directly referred for colonoscopy (i.e., no biopsy is performed).

For the year in which both FOBT and flexible sigmoidoscopy are due, the FOBT is performed first and if positive, the subject is referred for colonoscopy. Flexible sigmoidoscopy is done only for those with a negative FOBT.

If a follow-up colonoscopy is negative, then the subject is assumed to undergo subsequent screening with colonoscopy with a 10-year interval (as long as the repeat colonoscopy is negative) and does not return to the initial screening schedule, as is the recommendation of the Multi-Society Task Force (Winawer 2006). In other words, once a person has a colonoscopy, the individual remains on a colonoscopy schedule.

If adenomas are detected on colonoscopy then the individual begins surveillance with colonoscopy per the 2006 guidelines from the joint publication of the US Multi-Society Task Force and the American Cancer Society (Winawer 2006; Rex 2006). All individuals found with one or two adenomas that are both less than 10 mm in size will undergo colonoscopy surveillance every 5–10 years (5 years was used). Individuals with at least one adenoma greater than or equal to 10 mm in size or with 3 or more adenomas will undergo colonoscopy surveillance every 3 years unless the surveillance colonoscopy is normal or only detects one or two adenomas of size <1.0 cm, then the next surveillance colonoscopy would be at 5 years.

For the base-case analysis we assumed that all individuals are 100% adherent with screening, follow-up, and surveillance procedures. In sensitivity analysis we examined less than optimal adherence to determine if differences in adherence affect our results (see section on sensitivity analyses).

We specified a stop age of 80 for screening but allowed all individuals with an adenoma detected to continue to have surveillance colonoscopies until a diagnosis of CRC or death from other causes. All simulated individuals were followed until death. The life-years gained per scenario were derived relative to no screening.

## CRC Screening Test Characteristics

For the 2003 cost-effectiveness report to AHRQ and CMS on FIT we conducted a literature review for FIT, flexible sigmoidoscopy and colonoscopy (van Ballegooijen 2003). We updated that literature review for those tests and included the recent articles by Morikawa (2005 and 2007), Levi (2007), Vilkin (2005), Guitttet (2007), Fraser (2006), Smith (2006), and Allison (2007). The literature on the DNA stool test was summarized above. We assumed conditional independence for all screening tests. In other words, the sensitivity for detecting an adenoma or cancer depended only on the disease status at the time of the screen and did not depend on the test results from previous screening tests.

As noted in the 2003 FIT report (van Ballegooijen, 2003), the screening studies for Hemoccult SENSA and FIT are primarily based on higher-risk populations, who were already undergoing colonoscopy and were willing to do a pre-colonoscopy FOBT, or were studies where only the patients with positive tests were evaluated with colonoscopy. Consequently the test parameters for sensitivity from these studies could be higher than that found in a general population screening study.

### Fecal immunochemical test (FIT)

There are multiple FITs with varying cut points for positivity, number of slides, number of days tested, and preparations reported in the literature. In the 2003 report by van Ballegooijen we reviewed the literature for FIT, including HemeSelect, Monhaem, Flexsure, Magstream 1000 Hem SP, and Insure. The 2003 report was primarily based on the performance of the Insure test. We updated the estimates for FIT based on a large study on sensitivity and specificity of the Magstream 1000/Hem SP FIT (Morikawa 2005). The results of the Morikawa study for CRC were 66% sensitivity for CRC and 95% specificity for CRC which were similar to the estimates of sensitivity of 70% and specificity of 95% used in the previous report on FIT to AHRQ and CMS (van Ballegooijen 2003). Consequently we retained the estimates of FIT’s specificity and sensitivity for cancer from the previous report. However detection rates for adenomas were slightly higher than in the 2003 FIT report. Because the sensitivity estimates for adenomas in the 2003 report were based on limited data, we used the adenoma sensitivity estimates reported in the Morikawa papers (2005, 2007) for the current report. A new study by Allison (2007) for a FlexSure OBT (currently marketed as Hemoccult ICT by Beckman Coulter) had sensitivity for CRC of 82% and for advanced adenomas was 29.5%. Specificity for the FIT was 98%. The test characteristics used in this analysis are within the confidence intervals of this study.

### Hemoccult SENSA

We assumed that the sensitivities of Hemoccult SENSA for adenomas and CRC were similar to those of FIT. However specificity was assumed to be lower for Hemoccult SENSA (van Ballegooijen 2003). In addition to yielding more false-positive results, the lower specificity of Hemoccult SENSA results in a greater number of chance findings of adenomas; consequently adenoma detection with SENSA was considered to be slightly higher than with FIT. In the October 2007 paper by Allison, the sensitivity of Hemoccult SENSA for CRC was 64% (lower than for the FIT comparator) and for advanced adenomas was 41% (higher than for the FIT comparison). Specificity was 98% similar as that for the FIT comparator. Our sensitivity estimates for Hemoccult SENSA are within the confidence intervals of this study. The specificity is significantly higher than assumed in our analysis, but this high specificity is not corroborated by other studies.

### Hemoccult II

The estimated CRC sensitivity of Hemoccult II was not changed from the 40% estimated in the 2003 report which was based on a synthesis of the randomized controlled trials (Mandel 1993, Kronborg 1996 and Hardcastle (1996). This sensitivity is considerably higher than the 13% found by Imperiale (2004), but in line with the 47% that Ahlquist (2007) found. One of the reasons for this may be that in the Imperiale study Hemoccult II was not centrally processed. The 40% sensitivity figure is consistent with the randomized trial results according to earlier modeling studies (Gyrd-Hansen 1997, Hardcastle 1996) and other Hemoccult II studies (See Appendix A tables from the FIT cost-effectiveness report to CMS for an overview of studies). We assessed the effect of a lower sensitivity of Hemoccult II on the threshold costs of DNA stool screening in a sensitivity analysis. Sensitivities of Hemoccult II for adenomas were estimated by assuming the same ratio between adenoma sensitivity and CRC sensitivity as for FIT.

### Flexible sigmoidoscopy

We assumed the same sensitivity for flexible sigmoidoscopy as for colonoscopy within the reach of the scope. The reach of the flexible sigmoidoscopy is generally measured and reported in terms of centimeters of reach rather than location in the colon. However, the models represent adenomas and CRCs by location. We used the correspondence of location and centimeters from the anus from autopsy studies (Eide 1978) as well as the clinical study of Adam (2000) that used an electromagnetic imaging device to record the 3-dimensional position of the scope to estimate the reach for flexible sigmoidoscopy. In a Kaiser Permanente study, 60 cm or more of the colorectum was visualized in 63% of sigmoidoscopies, and at least 40 cm of the colorectum was reached in 83% of sigmoidoscopies (Doria-Rose 2004). We assumed that 80% of sigmoidoscopy examinations reach the junction of the sigmoid and descending colon and 40% reach the beginning of the splenic flexure.

### Colonoscopy

Sensitivity estimates for colonoscopy were based on a recent meta-analysis (van Rijn 2006). In screening studies the reach of the colonoscopy has been high with over 90% reaching the cecum. An incomplete colonoscopy should be followed by another colonoscopy or some other procedure to ensure that the entire colon is visualized. We therefore assume that 5% of subjects will have more than one colonoscopy to visualize the entire colon. In the models we assume that an average of 1.05 colonoscopies is performed per subject to obtain colonoscopic examination and that the cecum is reached in 98% of subjects.

Table 2 contains an overview of test characteristics used in our analyses.

Table 2 Estimates of test characteristics used in analysis

Test | Sensitivity^*^ by adenoma size or CRC (%) | | | | Specificity (%)
| ≤5 mm | 6–9 mm | ≥10 mm | CRC
FOBT Hemoccult II | 2.0 | 5.0 | 12.0 | 40.0 | 98.0
FOBT Hemoccult SENSA | 7.5 | 12.4 | 23.9 | 70.0 | 92.5
FIT | 5.0 | 10.1 | 22.0 | 70.0 | 95.0
DNA stool test (v1.0) | 5.0 | 12.0 | 15.0 | 52.0 | 95.0
DNA stool test (v1.1) | 4.0 | 12.0 | 43.0 | 70.0 | 96.0
DNA stool test (hypothetical version 2.0) | 15.0 | 22.1 | 55.0 | 90.0 | 85.0
Colonoscopy | 75.0 | 85.0 | 95.0 | 95.0 | 90.0^†^
Sigmoidoscopy^††^ | 75.0 | 85.0 | 95.0 | 95.0 | 92.0^†^

* Sensitivity is provided per individual for stool-based tests and per lesion for endoscopy tests.

† The lack of specificity with colonoscopy and sigmoidoscopy screening reflects the detection of non-adenomatous lesions. With colonoscopy these non-adenomatous lesions are removed and therefore induce polypectomy costs. With sigmoidoscopy the presence of non-adenomatous lesions induces biopsy costs (in case of sigmoidoscopy with biopsy) or results in referral for diagnostic colonoscopy (in case of sigmoidoscopy without biopsy).

†† Test characteristics for sigmoidoscopy only apply to the distal colon and rectum.

## Costs

The base-case cost-effectiveness analysis was conducted from the payer (CMS) perspective. We also conducted an analysis from a modified societal perspective by including direct costs borne by beneficiaries as well as estimated patient time costs, but excluding costs due to lost productivity caused by early death or disability. Screening costs were based on information provided by CMS on Medicare payments in 2007 for procedures and tests associated with CRC screening and complications of screening. Net costs of CRC related care were obtained from an analysis of SEER-Medicare linked data.

### Screening and complication costs

Costs for screening tests were based on the set of current procedural terminology (CPT) codes relevant to CRC screening in conjunction with the points of service for the procedures. The CPT codes for screening are those stated by the NCD (http://www.medicare.gov/health/coloncancer.asp) for the CRC screening benefit as well as those for associated colonic biopsy or polypectomy (personal communication, John Allen, M.D., and Joel Brill, M.D.). We used the national (i.e., unadjusted for geographic location) payment amounts under the Physician Fee Schedule (PFS) for these analyses. The unadjusted costs rather than the RVUs were used because they more directly reflected the costs for Medicare.

Payer cost for Hemoccult II, Hemoccult SENSA, FIT, and DNA stool test do not include additional charges for points of service because these costs are related only to the clinical laboratory fee schedule (http://www.cms.hhs.gov/ClinicalLabFeeSched/).

The PreGen-Plus was assumed to cost $350 per test based on private insurer reimbursement (Perrone 2007).

Points of service considered for screening were the Outpatient Prospective Payment System (OPPS) and the Ambulatory Surgery Center (ASC) Payment System with the associated facility charge, and the PFS office system. We did not include CPT codes for screening associated with inpatient procedures as registered in the Inpatient Prospective Payment System (IPPS) because screening endoscopies are not typically performed as inpatient procedures. The percentages of procedures by point of service were obtained from CMS. Given that in-patient procedures were excluded, the total percent does not sum to 100%. The percent per point of service out of the total percent for the OPPS, ASC, and PFS procedures were used as weights in obtaining an overall average cost for each procedure. Complication costs were based primarily on inpatient DRG-level reimbursement costs.

Screening procedure costs were based on a weighted average of procedures per setting. The cost values per setting and CPT code are given in Appendix 4. The costs for the ASC setting include the ASC payment rates and the PFS facility charge (Appendix 4, Table 2). The costs for the OPPS setting included the OPPS payment rates and the PFS facility charge (Appendix 4, Table 3). For the PFS office setting we used the office payment rates (Appendix 4, Table 4). The costs for colonoscopy without polypectomy were based on CPT codes 45378 (diagnostic colonoscopy), G0105 (colon screen in high risk individuals) and G0121 (colon cancer screening for non high risk individual). Costs for colonoscopy with polypectomy or biopsy were composed of codes 45380 (colonoscopy and biopsy), 45381 (colonoscopy, submucous injection), 45382 (colonoscopy/control bleeding), 45383 (lesion removal colonoscopy – fulguration), 45384 (lesion removal colonoscopy-hot biopsy) and 45385 (lesion removal colonoscopy-snare polypectomy).

We assumed that polypectomy was not performed with flexible sigmoidoscopy screening. However, we distinguished flexible sigmoidoscopy with and without biopsy. For flexible sigmoidoscopy without biopsy we used CPT codes 45330 (diagnostic sigmoidoscopy) and G0104 (CA screen; flexi sigmoidoscope). Flexible sigmoidoscopy with biopsy was based on CPT code 45331 (sigmoidoscopy and biopsy).

### Polyp removal and pathology review

For the procedures with polypectomy or biopsy we included a pathology charge (CPT code 88305). The Medicare payment rates per jar were $82.40 for the PFS office and ASC settings, and $51.59 for the OPPS setting. We assumed that all biopsies and removed polyps are reviewed by pathology and that a separate jar is submitted to pathology for each of 4 colon segments so that the resection area could be identified should the patient require surgery. Data from the National Colonoscopy Study were used to provide the estimate of 1.38 as the average number of jars per patient with polyps (hyperplastic, other polyps, and adenomas) (personal communication, Ann Zauber, Ph.D.). Consequently, we multiplied the pathology fee by 1.38 to obtain the average pathology cost associated with colonoscopy with polypectomy. Total costs per setting and CPT code are given with and without pathology charge (Appendix 4, Table 5).

Multiple polyps requiring the same type of polypectomy removal within a single colonoscopy do not add an incremental charge to the procedure. However if different types of polypectomy are required in removing multiple polyps then CMS reimburses 100% for the most expensive procedure and 50% of the facility cost for the second procedure. As a simplifying assumption we use the weights of procedures by CPT type and do not consider different fees for different combinations of endoscopy CPT codes for polyp removal.

The total costs per CPT code were weighted by the frequencies for points of service (Appendix 4, Table 6). The total costs per screening procedure were based on the total costs per CPT code that are part of the procedure and weighted by the frequencies of the CPT codes (Appendix 4, Table 7). If the colon is not adequately visualized, a repeat colonoscopy is typically performed. CMS reimburses the second colonoscopy at the same rate as for the initial colonoscopy. We assumed 5% of the colonoscopies are incomplete and need to be repeated. Instead of modeling incomplete colonoscopies, we increased the costs of a colonoscopy without polypectomy ($497.59) by 5%, resulting in $522.47. For colonoscopy with polypectomy we added the same absolute difference of $25, resulting in $673.4 (648.52 + 25). The additional $25 reflects repeat colonoscopies assuming that polyps were only removed at one of the two colonoscopies. The cost of sedation is included in the cost of colonoscopy, assuming that it is not administered by an anesthesiologist. The resulting costs per screening test are provided in Table 3.

Table 3 Screening tests costs based on the CMS cost reimbursement ($2007)

Screening test | CMS cost, $ | Modified societal cost, $
Guaiac Hemoccult (II or SENSA) | 4.54 | 21.54
Immunochemical fecal occult blood test (FIT) | 22.22 | 39.22
Flexible sigmoidoscopy | 160.78 | 270.30
Flexible sigmoidoscopy with biopsy | 348.19 | 497.37
Colonoscopy without polypectomy | 497.59 | 794.94
Colonoscopy with polypectomy or biopsy | 648.52 | 979.28
DNA stool test version 1.0 and version 1.1 (assumption) | 350.00 | 367.00

### Complications of screening

The harms as well as the benefits of screening must be taken into account. There are essentially no complications from the stool-based screening tests (Hemoccult II, SENSA, FIT, or DNA stool test) from the tests themselves. However patients undergoing colonoscopy and, to a lesser extent, flexible sigmoidoscopy are at risk of experiencing complications from the procedures. Since individuals with a positive sigmoidoscopy or stool-based test are referred for a follow-up colonoscopy, the complications and the associated costs are relevant and accounted for in all of the screening strategies.

Risks of complications reported in organized screening programs (Lieberman 2000, Regula 2006, Pox 2007) are lower than those reported for general practice colonoscopies. (Levin 2002, 2006) and have not focused on the older ages. Also risks of complications of colonoscopy have declined over time. The major complications of colonoscopy are perforations, which can occur with or without polypectomy, serosal burns, bleeds requiring transfusion and bleeds not requiring transfusion (Levin 2006, Lieberman 2000, Pox, 2005, Klabunde (2007), and personal communication from Drs. John Allen and Joel Brill). Dehydration was also cited as a complication of colonoscopy in an assessment in the Medicare population (personal communication; Joan Warren, Ph.D. and Carrie Klabunde, Ph.D). All available data were used in deriving the complication rate estimates (Table 4).

The costs of complications were based on the relevant DRG codes. We assumed that a patient with a perforation or a bleed with transfusion would require hospitalization and that a patient with a bleed that does not require transfusion would be treated in an emergency room visit. The cost of perforation was based on DRG 442 (other OR procedures for injuries with colon cancer) and bleeding with transfusion was based on DRG 452 (complications with treatment of colon cancer). A patient with a serosal burn generally requires a two-day hospitalization, which we assumed to cost the same as a bleed with transfusion.

We estimated a rate of death among persons with a therapeutic colonoscopy (i.e., a colonoscopy with adenoma removal) of 1 per 10,000 (Jentschura 1994). A summary of the costs and risks of complications is provided in Table 4.

Table 4 Summary of costs and risks of endoscopy complications

Complication | Rate per 1000 | Cost, $2007
With colonoscopy
Perforation | 0.7 | 12,446
Serosal burn | 0.3 | 5,208
Bleed with transfusion | 0.4 | 5,208
Bleed without transfusion | 1.1 | 320
With flexible sigmoidoscopy
Perforation | 0.02 | 12,446

### Costs for colorectal cancer treatment

The cost of CRC treatment was derived from comparison of costs for CRC cases relative to those of matched controls in the SEER-Medicare files (personal communication, Robin Yabroff, Ph.D. and Martin Brown, Ph.D.). The methods used to estimate phase-specific costs of CRC were based on a previous analysis of SEER-Medicare data (Brown 1999). Cost data were reported in 2004 dollars and subsequently updated to 2007 dollars using the medical care component of the Consumer Price Index (CPI). While there is some differing of opinion about the use of the medical care component of the CPI vs. the overall index, the difference between the two is not large for this period of time.

Patients with a diagnosis of invasive CRC between 1973 and 2002 and aged 65 or above at some time between 1998 and 2003 were selected from SEER-Medicare (N = 124,793). Cancer patients with a prior cancer diagnosis (N= 20,277), or who were identified as having cancer through a death certificate or autopsy were excluded (N=623). An additional 24,920 patients were excluded because they were enrolled in managed care throughout the observation period or did not have both Medicare part A and part B at any point during the observation period. The remaining 76,722 CRC patients were included.

Potential controls were individuals without any cancer diagnoses recorded by SEER and aged 65 or above during the observation period, 1998–2003. A total of 170,491 controls were selected from a 5% random sample of Medicare enrollees and frequency matched to cases by gender, 5-year age strata (65–69, 70–74, 75–79, 80+) and SEER registry areas.

Phase of care definitions. Phase of care definitions were based on prior studies of direct medical costs. For cancer patients, months of observation and cost of care between 1998 and 2003 were divided into three clinically relevant phases of care – initial, last year of life, and continuing care based on the month of service on the Medicare claim. Date of death (or its absence) in the Medicare enrollment file through 2004 was used to determine vital status. Cause of death (cancer, non-cancer) was identified from SEER. The initial phase was defined as the first 12 months following diagnosis, the last-year-of-life phase was defined as the final 12 months of life, and the continuing phase was defined as all months between the initial and last-year-of-life phases of care. Not all cancer patients contributed to all phases of care, however. For patients surviving less than 24 months after diagnosis, the final 12 months of observation and costs of care were then allocated first to the last-year-of-life phase, because the content of care for patients with short survival is more similar to the last–year-of-life phase than the initial phase. The remainder of months of observation and costs were allocated to the initial phase, with no contribution to the continuing phase. Patients diagnosed prior to 1997 who survived beyond 2003 contributed months and costs of care only to the continuing phase. Within each tumor site and phase of care, average monthly estimates of cost of care were calculated.

Because control subjects did not have a date of cancer diagnosis, they were randomly assigned a “pseudo-diagnosis date” that corresponded to the date of diagnosis of one of the pool of cancer cases. Months of observation and costs of care were assigned to phases of care in the same manner used with cases. In addition to frequency matching by gender, 5-year age group and SEER area strata, controls were also matched to cases by phase of care. To reflect costs associated with cancer care in the last year of life, cancer patients who died of cancer were matched to continuing controls, and cancer patients who died of other causes were matched to last-year-of-life controls. As with cancer patients, average monthly estimates of cost of care were calculated for each phase of care for each of group of controls. For months in which patients received coverage through managed care or were without both Medicare part A and part B, costs and months of observation time were excluded because these data would not completely capture the care received during this period.

Cost estimates. Cancer-related medical costs were estimated as differences in costs for cases and controls by phase of care. The analysis used Medicare payments to reflect costs of care, rather than billed charges. Payments for Medicare Part A (inpatient services) and Part B (outpatient services) were calculated separately. The Hospital Wage Index and the Medicare Economic Index were used to adjust for inflation in Medicare Parts A and B estimates, respectively, during 1998–2003. We also adjusted for geographic variability in costs of care across SEER sites. New treatments including biologicals, such as Avastin and Erbitux (Schrag 2004), have come into use in the past 3 years; these new drugs are markedly more expensive than the previous drugs. However the cost of these new drugs would not be captured by the 2004 reimbursement base available for this case-control study. The costs that were used as model inputs from the payer perspective are shown in the top half of Table 5.

Table 5 Net payments for CRC care during 1998–2003 (in $2007)^*^

| | | Last Year of Life
AJCC Stage | Initial Phase | Continuing Phase | Died of Cancer | Died of Other Causes
[underlined: Direct Medical Costs]
I | 25,487 | 2,028 | 45,689 | 11,257
II | 35,173 | 1,890 | 45,560 | 9,846
III | 42,885 | 2,702 | 48,006 | 13,026
IV | 56,000 | 8,375 | 64,428 | 34,975
[underlined: Modified Societal Costs]
I | 32,720 | 2,719 | 56,640 | 17,408
II | 43,752 | 2,561 | 56,417 | 15,740
III | 53,003 | 3,573 | 59,481 | 19,413
IV | 68,853 | 10,743 | 78,227 | 44,384

* The initial phase of care is the first 12 months following diagnosis, the last-year–of-life phase is the final 12 months of life, and the continuing phase is all the months between the initial and last-year-of-life phases. Cancer-related costs in the continuing phase of care are an annual estimate.

### Out-of-pocket and time costs

In a sensitivity analysis we added beneficiary costs (co-payments) and time costs to the payer costs for a modified societal perspective. We label this perspective a “modified societal perspective” because while we include the above costs, we do not incorporate productivity costs.

Beneficiary costs associated with screening tests were based on the CMS co-payment per point of service and type of CPT code. To incorporate patient time costs associated with CRC screening we assumed that the value of patient time was equal to the median US wage rate in 2007 from the Bureau of Labor Statistics, $16.64 per hour. We assumed that endoscopy screening requires preparation and recovery. We assumed that the time associated with a colonoscopy procedure was 8 hours and with flexible sigmoidoscopy was 4 hours. Patient time requirements for stool-based screen tests (e.g., Hemoccult II, Hemoccult SENSA, FIT and DNA stool test) were assumed to be 1 hour. For treatment of complications with colonoscopy and sigmoidoscopy, we assumed that patient time requirements would be on average16 hours. Modified societal costs for screening are given in the right-hand size of Table 3.

The beneficiary costs for treatment were also derived based on the copayment and time costs. Estimated patient deductibles and coinsurance expenses were added by adjusting Part A and Part B payments with Medicare reimbursement ratios provided by the CMS Office of the Actuary. Over the time period studied, these averaged about 8% for Part A and about 30% for Part B. Estimates of time costs for cancer care were from a recently published analysis of the SEER-Medicare linked data (Yabroff 2007) and updated to 2007 dollars using the Consumer Price Index. This study estimates the frequencies of relevant medical services, including physician office visits, emergency room visits, chemotherapy, radiation therapy, hospitalizations, imaging procedures, and ambulatory surgeries. Average service frequencies were then combined with estimates of patient time for each category of service, and the value of patient time was then assigned. Net patient time costs associated with cancer care were calculated by subtracting mean values for control subjects from mean values for patients by service category in the initial, continuing, and last-year-of-life phases of care. Total time costs were estimated to be $4,052 for the initial phase of care and $4,705 for the last-year-of-life phase of care. These estimates of time costs are a somewhat different than estimates reported previously (Yabroff 2005), primarily due to refined methods and a longer observation period, and inclusion of additional services (i.e., imaging procedures). In that 2005 study the time costs associated with initial, continuing (per month), and terminal phases were $4592, $25, and $2788, respectively. Because the 2007 analysis did not provide time costs for the continuing phase of care, we used a monthly cost of $27. The treatment costs that were used as model inputs from the payer perspective are shown in the bottom half of Table 5.

## Analysis

### Outcomes

Using the base-case inputs, we used each model to project a number of outcomes for each screening strategy. These outcomes include the number of cancers detected, number of cancer deaths averted, life expectancy (discounted and undiscounted) and the lifetime CMS costs (discounted and undiscounted). Differences in results across models reflect the different underlying natural history models.

### Incremental cost-effectiveness analysis

For each model, we ranked the 17 screening strategies by increasing effectiveness (i.e., discounted number of life-years gained compared with no screening). Strategies that were more costly and less effective than another strategy were ruled out by simple dominance. Strategies that were more costly and less effective than a combination of other strategies were ruled out by extended dominance. Remaining strategies were then rank ordered by increasing costs and effectiveness, and incremental cost-effectiveness ratios (ICERs) were calculated by dividing the incremental discounted cost by the incremental discounted life-years gained, relative to the next least expensive option. These strategies represent the set of efficient options. On a plot of costs vs. life-years gained, a line that connects the efficient strategies is called the efficient frontier, and all dominated strategies (simple or extended) lie below this line. If none of the DNA stool test strategies lie on the efficient frontier, we then determined the degree to which each of the following parameters would have to change in order for one of the DNA stool test strategies to reach the frontier: unit cost of the DNA stool test, diagnostic performance of the DNA stool test, or relative adherence with the DNA stool test compared with other screening tests.

### Threshold analysis

Next, we identified threshold costs for the DNA stool test using the version 1.0 and version 1.1 assumptions. For each DNA stool test strategy, we calculated the maximum costs of a single DNA stool test for the strategy to be part of the efficient frontier. There were three possible situations to consider when including one of the DNA stool test strategies as an efficient strategy: (1) the DNA stool test strategy was less effective than the least effective strategy on the efficient frontier, (2) the DNA stool test strategy was more effective than the most effective strategy on the efficient frontier, and (3) the effectiveness of the DNA stool test strategy was intermediate to the least effective and most effective strategies on the efficient frontier.

In the first case the threshold costs of the DNA stool test were calculated such that the ICER for the least effective efficient strategy compared with the DNA stool test strategy is equal to the previous ICER of the next least effective efficient strategy (prior to the addition of the DNA stool test strategy). In the second case the threshold test costs were calculated such that the ICER for the DNA stool test strategy compared with the most effective efficient strategy is equal to $100,000 per life-year gained. In the third case we identified the efficient strategy with lowest life-years gained that would still have more life-years gained than the DNA stool test strategy. Subsequently the threshold costs were calculated such that the ICER of the DNA stool test strategy is equal to the ICER of that selected strategy.

While calculating ICERs for competing alternatives is the theoretically correct approach for optimizing the health of a population under constrained resources (Gold 1996), we also determined threshold costs for the DNA stool test such that the test strategy has the same average cost-effectiveness ratio (ACER) as at least one other recommended CRC screening strategy. ACERs represent the incremental cost per life-year saved of each strategy relative to no screening. We calculated the per-test cost that would allow a DNA stool test strategy to have the same ACER as the non-DNA stool test strategy with the lowest and the highest ACER values. When the strategy with the lowest ACER was cost-saving we calculated the per-test cost for the DNA stool test that would make that strategy cost neutral (i.e., the same lifetime discounted costs as no screening). The disadvantage of this latter approach is that with the threshold costs calculated this way, the DNA stool test strategy could be less effective and more costly than other screening strategies.

### Sensitivity analysis

In analyses of the impact of alternative assumptions about key model parameters (often called sensitivity analyses), it is customary to vary the uncertain parameters around the best estimates (i.e., the base-case estimates). We anticipated that DNA stool testing, based on evidence available to date, would not be cost-effective when compared with the other CRC screening tests, given that the DNA stool test was not more sensitive or specific than Hemoccult SENSA and yet almost 80 times as expensive. Therefore, we focused our sensitivity analyses on varying the diagnostic performance characteristics in only a more favorable direction. In addition, we varied the test performance of the DNA stool test beyond what is clinically plausible; namely, a perfect test. This represents a solely hypothetical scenario.

The NCD is requested for PreGen-Plus (i.e., DNA stool test version 1.1) based on Whitney (2004). Version 2.0 is in development based on the training set analysis of the Itzkowitz study where sensitivity for cancer was 88% and specificity 82%. Given the potential for further evolution of the DNA stool test, we created a hypothetical best-case version 2.0 with 90% sensitivity and 85% specificity. The sensitivity for adenomas by size was increased proportionally by the same increase (29%) as for the increase in sensitivity for cancer from version 1.1 to version 2.0.

We identified the threshold DNA stool test costs for this scenario and other hypothetical scenarios in which the diagnostic performance of the DNA stool test was varied from the base-case version 1.1 values to the perfect test assumption. The sensitivities for small, medium, large adenomas and cancer, as well as the specificity of the base-case estimate were increased by a percentage of the difference between the base-case values (version 1.1) and perfect sensitivity and specificity. The percentages used were 10%, 25%, 50%, 75% and 100% and were multiplied by the difference between perfection (sensitivity and specificity of 1.0) and the version 1.1 base-cases values and added to the base-case version 1.1 values (Table 6).

Table 6 DNA stool test sensitivity and specificity values used in sensitivity analysis

Test Assumption | Sensitivity by adenoma size or CRC, % | | | | Specificity (%)
| ≤5 mm | 6–9 mm | ≥10 mm | Cancer
sDNA (v1.1) | 4 | 12 | 43 | 70 | 96
sDNA (v1.1) + 10% | 13 | 20 | 48 | 73 | 96
sDNA (v1.1) + 25% | 27 | 33 | 57 | 77 | 97
sDNA (v1.1) + 50% | 51 | 55 | 71 | 85 | 98
sDNA (v1.1) + 75% | 75 | 77 | 85 | 92 | 99
sDNA (v1.1) + 100% | 100 | 100 | 100 | 100 | 100

We also identified threshold DNA stool test costs of scenarios where we allowed the adherence of DNA stool test strategies to be greater than that of all other screening strategies. We took an approach similar to examining DNA stool test characteristics to assess the impact of differential adherence with a DNA stool test compared with other screening tests. Our base-case analysis assumes that 100% of participants adhere to recommendations for the screening tests. Some have suggested that use of DNA stool testing might entice a previously unscreened individual to undergo screening because it is non-invasive, requires no dietary restrictions or bowel preparation, and can be conducted at home and shipped from any location. Schroy (2005) assessed the patients’ test preferences in the Imperiale study and found more people preferred the DNA stool test (45%) than Hemoccult II (32%) or colonoscopy (15%). To test the impact of differential adherence rates on the threshold DNA stool test cost, we conducted a sensitivity analysis on adherence where we first started with a more realistic adherence rate for all tests of 50%. We assumed that an individual would be either 100% adherent to a screening strategy or non-adherent. The impact of modeling adherence in this fashion is the it does not alter the ICERs and it allows us to evaluate the impact of enhancing screening with the DNA stool test in a previously unscreened segment of the population. We then allowed adherence for the DNA stool test strategy to be better than the other primary screening tests, which were set at an adherence rate of 50%. The adherence with the DNA stool test strategy was varied from 50% to 55%, 62.5%, 75%, 87.5% and 100% representing a 10%, 25%, 50%, 75% and 100% increase in adherence.

Since a previous analysis of the cost-effectiveness of the DNA stool test by Song and colleagues (2004) concluded that DNA stool testing every two years with a per-test cost of $195 resulted in life-years gained and costs comparable to those of colonoscopy screening every ten years, we also evaluated the threshold costs DNA stool test costs using a two-year screening interval. We also evaluated the cost-effectiveness of DNA stool testing among a cohort of 50-year-olds, since current recommendations suggest that individuals at average risk begin CRC screening at age 50.