# CONCLUSIONS

The results of this cost-effectiveness analysis suggest that the DNA stool test (version 1.1) does provide a benefit in terms of life-years gained compared with no screening but the cost, relative to the benefit derived and to the availability and costs of other CRC tests, would need to be in range of $34 to $51 for 5-yearly DNA stool testing and $40–$60 for 3-yearly DNA stool testing to be a non-dominated strategy, provided that the estimates of sensitivity and specificity as stated from the Whitney study (2004) are obtained in a screening setting. These estimates are based on the analysis of an unscreened 65-year-old cohort using a payer perspective. Threshold costs are similar for a 50-year old cohort (range of threshold test costs: $27 to $52), but can be somewhat higher when the analysis is performed using a modified societal perspective ($88 to $134 for 5-yearly testing and $73 to $116 for 3-yearly testing).

There is a potential for the DNA stool test as a CRC screening test in an average-risk population, especially if a two-marker assay were to be developed with lower cost. However, further testing and validation in a population-based screening setting is required to ensure that the test parameters are achieved in an assay with fewer markers and that the specificity can be kept as high if not higher. The well-designed trial by Imperiale evaluated the DNA stool test in a screening population. The Imperiale results suggested that the DNA stool test in a screening setting had higher sensitivity but worse specificity than the Hemoccult II test and carried a considerably higher cost than the Hemoccult II test. The version 1.1 DNA stool test has not been tested in a screening setting. Studies in a symptomatic population suggest that stool DNA testing has sensitivity for CRC comparable to that of the FIT, with higher sensitivity for large adenomas than FIT, and comparable specificity as FIT, but also with a considerably higher cost than FIT.

Certainly, if DNA stool screening were to be adopted by a significant number of individuals who would not have been screened otherwise, its relative value would increase substantially. However, this behavior would have to coincide with high adherence rates with follow-up and surveillance colonoscopy.

Finally, we conclude that the science is promising for the use of DNA stool-based technology in the future. However, the current evidence suggests that this test is not a cost-effective screening tool if the cost were to remain as high as $350.