# BACKGROUND

Colorectal cancer (CRC) is the second most common cause of cancer-related death in the United States (American Cancer Society 2007). It is estimated that 153,760 CRC cases will be diagnosed in 2007 with 52,180 deaths. The lifetime risk of being diagnosed with CRC is 5.7% for men and 5.2% for women; the lifetime risk of dying from CRC is 2.3% and 2.1% in men and women, respectively (Ries 2007). Approximately 70% of CRCs are diagnosed in persons over the age of 65; more than 90% are diagnosed over the age of 50. Only one-third of cases are detected at an early more curable stage.

The adenoma-carcinoma sequence is considered to be the primary pathway to CRC. In the 1970s the pathologist Basil Morson conceptualized that the adenoma was the precursor lesion for CRC (Morson 1978). Screening for CRC, and its precursor lesion the adenomatous polyp, can effectively reduce CRC mortality. Randomized trials of CRC screening with a fecal occult blood test (FOBT) show a 15% to 33% reduction in CRC mortality with screening (Mandel 1993, 1999; Kronborg 1996, Hardcastle 1996) and an 18% reduction in CRC incidence (Mandel 2000). Observational studies also show that endoscopic polypectomy can markedly reduce CRC incidence and mortality (Winawer 1993, Selby 1992), and randomized controlled trials of screening with flexible sigmoidoscopy are currently in the field (Atkin 2001, Segnan 2002, Prorok 2000). Despite this demonstrated benefit of CRC screening, participation in CRC screening is less than 50% in the US population of those aged 50 or older (Seeff 2004).

Currently the U.S. Preventive Services Task Force (USPSTF) (US Preventive Services Task Force 2002, Pignone 2002a), the Gastroenterology Multi-Society Task Force (Winawer 1997, 2003, 2006), and the American Cancer Society (Smith 2006, Winawer 2006) advocate screening for CRC for asymptomatic average-risk individuals, starting at age 50. The USPSTF concluded that there was insufficient information to recommend one screening strategy over another and recommended a range of screening options including FOBT, flexible sigmoidoscopy (with or without FOBT) or colonoscopy. Before July 1, 2001, Medicare law allowed coverage of screening colonoscopies once every 2 years for individuals at high risk for CRC. Individuals not a high risk for CRC qualified for coverage of CRC screening with FOBT, flexible sigmoidoscopy, and barium enema. The Medicare, Medicaid, and SCHIP Benefits Improvement and Protection Act of 2000, however, added coverage of screening colonoscopies once every 10 years for average-risk individuals.

New CRC screening tests, such as the fecal immunochemical test (FIT) and the DNA stool test have been introduced. In 2003 the MISCAN-Colon investigators provided a cost-effectiveness analysis of FIT to the Agency for Healthcare Research and Quality (AHRQ) for the Centers for Medicare and Medicaid Services (CMS) to inform the decision whether to cover FIT and, if so, at what reimbursement fee (van Ballegooijen 2003). For this report on DNA stool testing, two modeling groups (MISCAN and SimCRC) conducted a similar cost-effectiveness analysis to that of FIT to estimate the threshold cost for a DNA stool test relative to currently established screening guidelines. This report was initiated in response to a request for national coverage determination (NCD) on the use of a DNA stool test-version 1.1 (the PreGen-Plus™ test) for CRC screening among average-risk individuals every 5 years. Details can be found at http://www.cms.hhs.gov/mcd/viewtrackingsheet.asp?id=212.

Vogelstein and colleagues (Vogelstein 1988, Fearon & Vogelstein 1990) described the adenoma-carcinoma sequence as a series of genetic mutations in the APC, K-ras, and p53 genes. They also showed that human DNA from cells shed from the colonic epithelium could be detected in stool. These observations are the basis of the DNA stool test, which is designed to detect these mutations in stool samples as a marker for CRC. Whether such markers from genetic mutations in the stool provide a good screening test is under investigation. The first DNA stool screening test, based on the work of Vogelstein and colleagues work and technologies developed by EXACT Sciences Corp., was developed into a testing service by Laboratory Corporation of America Holdings (LabCorp) and became commercially available in August 2003. Marketed as PreGen-Plus, the assay was composed of 23 molecular markers associated with CRC and pre-malignant neoplasms. These markers include 21 point mutations among the APC, K-ras, and p53 genes, one microsatellite instability marker, BAT-26, for epigenetic factors, and a DNA Integrity Assay (DIA®) for long non-apotototic DNA.

The DNA stool test had had several improvements in the development of version 1.0 (Ahlquist 2000, Tagore 2003, Calistri 2003, Brand 2004, Syngal 2006) and for the currently available version 1.1 (Whitney 2004). Further developments include a vimentin marker (Chen 2005, Itzkowitz 2007) for a version 2.0 to be commercially available in the future. Additional improvements are to be expected in the future. This report uses the DNA stool test version 1.1 (i.e., PreGen-Plus) as the base case for analysis in accordance with the NCD but we also consider the DNA stool test version 1.0 as an alternative base case.

In this report we first summarize the evidence on the sensitivity and specificity of the DNA stool test. Using the best evidence for the test parameters, we then conduct simulations to determine what the reimbursement cost from CMS to providers would have to be for the DNA stool test in order for it to be considered comparable to other CRC screening tests from a cost-effectiveness standpoint. To accomplish this we use microsimulation modeling to project lifetime costs, life-years gained, and cost-effectiveness ratios for various CRC screening strategies (including DNA stool test strategies). To add robustness to the results we use two microsimulation models, each developed independently by modelers affiliated with the Cancer Intervention and Surveillance Modeling Network (CISNET) – a modeling consortium funded by the National Cancer Institute (NCI) that focuses on the use of modeling to improve our understanding of the impact of cancer control interventions (e.g., prevention, screening treatment) on population trends in incidence and mortality. The two simulation models, MISCAN and SimCRC, incorporate the best available evidence on the natural history of colorectal disease and the screening test characteristics to project outcomes such as life-years gained compared with no screening and the expected number of colonoscopies performed. Both models were among the first to assess the cost-effectiveness of different screening modalities for CRC. The results of the two models will be compared; comparable results strengthen the credibility of the findings.