# Results for a cohort of 50-year-olds

Table A.6.1 Discounted costs and life-years gained per 1,000 50-year-olds without CRC screening and with 16 CRC screening strategies and associated incremental cost-effectiveness ratios (ICERs)

| MISCAN | | | SIMCRC
Strategy | Discounted costs, $ | Discounted life- years gained | ICER, $/LYG | Discounted costs, $ | Discounted life- years gained | ICER, $/LYG
No Screening | 2,320,612 | 0.0 | --- | 2,036,136 | 0 | d
sDNA-5 (v1.1) | 3,642,389 | 53.2 | d | 2,726,214 | 78.2 | d
sDNA-5 (v1.0) | 4,211,263 | 68.4 | d | 3,094,526 | 50.3 | d
sDNA-3 (v1.1) | 3,516,538 | 70.7 | d | 3,179,868 | 94.4 | d
sDNA-3 (v1.0) | 4,070,936 | 84.0 | d | 3,550,184 | 69.1 | d
HII | 2,368,129 | 85.3 | 600 | 1,638,377 | 90.6 | ---
HS | 2,614,056 | 100.1 | 16,600 | 1,741,434 | 108.8 | 5,700
FIT | 2,686,825 | 99.7 | d | 1,822,228 | 107.8 | d
SIGB | 2,725,052 | 88.4 | d | 1,927,596 | 82.5 | d
SIG | 2,759,328 | 91.7 | d | 1,939,260 | 89.8 | d
HII + SIGB | 2,832,993 | 102.5 | d | 1,849,712 | 110.8 | d
HII + SIG | 2,824,003 | 102.5 | d | 1,867,650 | 112.1 | d
HS + SIGB | 2,954,756 | 104.4 | 79,400 | 1,972,598 | 115.9 | 32,500
HS + SIG | 2,935,288 | 104.1 | d | 1,995,878 | 116.3 | 62,200
FIT + SIGB | 3,090,981 | 105.0 | 105,800 | 2,098,370 | 116.1 | d
FIT + SIG | 3,059,692 | 104.5 | d | 2,126,315 | 116.5 | 741,500
COL | 3,010,788 | 102.1 | d | 2,086,929 | 115.6 | d

--- indicates default strategy (i.e., the least costly and least effective non-dominated strategy)

d dominated

Table A.6.2 Threshold analysis on DNA stool test characteristics: unit costs for DNA stool costs resulting in equal cost-effectiveness (ACER and ICER) compared to current recommended CRC screening strategies for different combinations of test sensitivity and specificity for colorectal cancer screening beginning at age 50^*^

| Screening and counting from age 50
| sDNA (v1.0) | sDNA (v1.1) | sDNA (v2.0)
5-yearly DNA stool testing
On efficient frontier | NT, 8^‡^ | 37^‡^, 41^‡^ | NT, 10
Cost-neutral vs. no screening | NT, 49 | 24, 154 | NT, 142
Equal to highest ACER | 60, 100 | 165, 171 | 167, 168
3-yearly DNA stool testing
On efficient frontier | NT, 3^‡^ | 27^‡^, 52 | 4, 27
Cost-neutral vs. no screening | NT, 49 | 18, 126 | NT, 112
Equal to highest ACER | 60, 88 | 135, 140 | 134, 134

ACER = average cost-effectiveness ratio compared with no screening (calculated using discounted costs and life-years gained)

ICER = incremental cost-effectiveness ratio (calculated using discounted costs and life-years gained)

NT = no threshold found (i.e., negative DNA stool test cost)

* MISCAN values in plain text; SimCRC values in italics

‡ DNA stool test strategy is on the frontier as the least effective and least costly non-dominated strategy if the cost is at most this amount