# Additional outcomes of the analyses

Table A.5.1 Discounted costs and discounted life-years gained per 1,000 65-year olds and average cost-effectiveness ratios, by CRC screening scenario – MISCAN

Scenario | Discounted Costs, $ | Net Discounted Costs, $ | Discounted LYG | ACER, $/LYG
No Screening | 2,714,556 | 0 | 0 | NA
sDNA-3 (v1.0) | 3,860,227 | 1,145,671 | 51 | 22,300
sDNA-5 (v1.0) | 3,533,981 | 819,425 | 41 | 20,046
sDNA-3 (v1.1) | 3,673,499 | 958,943 | 68 | 14,105
sDNA-5 (v1.1) | 3,382,910 | 668,354 | 59 | 11,375
HII | 2,630,626 | −83,930 | 65 | CS
HS | 2,715,327 | 771 | 80 | 10
FIT | 2,776,790 | 62,234 | 79 | 784
SIGB | 2,823,196 | 108,640 | 74 | 1,463
SIG | 2,810,490 | 95,934 | 76 | 1,258
HII + SIGB | 2,793,754 | 79,198 | 84 | 941
HII + SIG | 2,840,538 | 125,982 | 85 | 1,488
HS + SIGB | 2,863,769 | 149,213 | 87 | 1,714
HS + SIG | 2,909,359 | 194,803 | 87 | 2,237
FIT + SIGB | 3,025,571 | 311,015 | 87 | 3,569
FIT + SIG | 2,992,773 | 278,217 | 87 | 3,190
COL | 2,906,064 | 191,508 | 86 | 2,222

ACER = average cost-effectiveness ratio compared with no screening; LYG = life-years gained compared with no screening; NA = not applicable; CS = cost-saving

Table A.5.2 Discounted costs and discounted life-years gained per 1,000 65-year olds and average cost-effectiveness ratios, by CRC screening scenario – SimCRC

Scenario | Discounted Costs, $ | Net Discounted Costs, $ | Discounted LYG | ACER, $/LYG
No Screening | 2,295,628 | NA | 0 | NA
sDNA-3 (v1.0) | 3,473,214 | 1,177,586 | 42 | 27,927
sDNA-5 (v1.0) | 3,147,621 | 851,993 | 29 | 29,757
sDNA-3 (v1.1) | 3,081,338 | 785,710 | 64 | 12,233
sDNA-5 (v1.1) | 2,814,315 | 518,688 | 51 | 10,089
HII | 2,121,988 | −173,640 | 58 | CS
HS | 2,078,632 | −216,995 | 76 | CS
FIT | 2,155,730 | −139,898 | 75 | CS
SIGB | 2,189,080 | −106,547 | 59 | CS
SIG | 2,176,765 | −118,862 | 62 | CS
HII + SIGB | 2,127,263 | −168,365 | 79 | CS
HII + SIG | 2,113,618 | −182,010 | 80 | CS
HS + SIGB | 2,187,768 | −107,860 | 85 | CS
HS + SIG | 2,187,042 | −108,586 | 85 | CS
FIT + SIGB | 2,282,357 | −13,271 | 85 | CS
FIT + SIG | 2,283,025 | −12,602 | 85 | CS
COL | 2,199,809 | −95,819 | 85 | CS

ACER = average cost-effectiveness ratio compared with no screening; LYG = life-years gained compared with no screening; NA = not applicable; CS = cost-saving