# Comparison of the two models on natural history outcomes

MISCAN | | | | | | SimCRC
Adenoma prevalence, age 65: 39.8% | | | | | | Adenoma prevalence, age 65: 37.1%
Number of adenomas per 1000 by site and size, age 65 | | | | | | Number of adenomas per 1000 by site and size, age 65
| <5mm | 6–9mm | 10+mm | | | | <5mm | 6–9mm | 10+mm
Prox | 121.2 | 69.9 | 61.8 | | | Prox | 171.8 | 185.8 | 23.9
Distal | 134.4 | 77.4 | 68.4 | | | Distal | 123.9 | 18.3 | 41.4
Rectum | 133.5 | 76.8 | 68.1 | | | Rectum | 8.7 | 16.0 | 15.6
Distribution of adenomas by site and size, age 65 (%) | | | | | | Distribution of adenomas by site and size, age 65 (%)
| <5mm | 6–9mm | 10+mm | total | | | <5mm | 6–9mm | 10+mm | total
Prox | 15 | 9 | 8 | 31 | | Prox | 28 | 31 | 4 | 63
Distal | 17 | 10 | 8 | 35 | | Distal | 20 | 3 | 7 | 30
Rectum | 16 | 9 | 8 | 34 | | Rectum | 1 | 3 | 3 | 7
CRC incidence among cancer-free 65-year-old population, % | | | | | | CRC incidence among cancer-free 65-year-old population, %
| Stage1 | Stage2 | Stage3 | Stage4 | Total | | Stage1 | Stage2 | Stage3 | Stage4 | Total
10-year | 0.4 | 0.7 | 0.5 | 0.5 | 2.1 | 10-year | 0.4 | 0.7 | 0.5 | 0.5 | 2.1
20-year | 0.8 | 1.6 | 1.0 | 1.0 | 4.4 | 20-year | 0.8 | 1.5 | 1.0 | 1.2 | 4.4
lifetime | 1.0 | 2.1 | 1.3 | 1.3 | 5.7 | lifetime | 0.9 | 1.9 | 1.3 | 1.5 | 5.7