# Model Descriptions

[underlined: Microsimulation models.] The MISCAN and SimCRC models from the NCI CISNET program are used to address the question of the cost-effectiveness of DNA stool testing. The models used common inputs and assumptions concerning the screening tests but use their independently developed natural history models in addressing these questions.

## Appendix 2A Description of the MISCAN-COLON model for natural history and intervention

### MISCAN Model overview

MISCAN-COLON is a semi-Markov microsimulation program to simulate the effect of screening and other interventions on colorectal cancer (CRC) incidence and mortality. With microsimulation we mean that each individual in the population is simulated separately. The model is semi-Markov in the sense that:

- distributions other than exponential are possible in each disease state
- transitions in one state can depend on transitions in earlier states,
- transitions can be age and calendar time dependent

All events in the model are discrete, but the durations in each state are continuous. Hence, there are no annual transitions in the model.

The development of CRC in the model is assumed to occur according to the adenoma carcinoma sequence. This means that adenomas arise in the population, some of which eventually develop into CRC. We assume that there are two types of adenomas: progressive and non-progressive adenomas. Non-progressive adenomas can grow in size, but will never develop into a cancer. Progressive adenomas have the potential to develop into cancer, if the person in whom the adenoma develops lives long enough.

All adenomas start as a small (1–5 mm) adenoma. They can grow in size to medium (6–9 mm) and large (10+ mm) adenoma. Progressive medium and large adenomas can transform into a malignant cancer stage I, not yet giving symptoms (preclinical cancer). The cancer then progresses from stage I (localized) eventually to stage IV (distant metastasis). In each stage there is a probability of the cancer giving symptoms and being clinically detected. The time between the onset of a progressive adenoma and the clinical detection of CRC is assumed to be on average 20 years. After clinical detection a person can die of CRC, or of other causes based on the survival rate. The survival from CRC is highly dependent on the stage in which the cancer was detected.

### MISCAN Simulation of an individual

Figure 2a shows how the model generates an individual life history. First MISCAN-COLON generates a time of birth and a time of death of other causes than CRC for an individual. This is shown in the top line of figure 2a. This line constitutes the life history in the absence of CRC. Subsequently, MISCAN-COLON generates adenomas for an individual. For most individuals no adenomas are simulated, for some multiple. In this example MISCAN-Colon has generated two adenomas for the individual. The first adenoma occurs at a certain age and grows in size from small to medium and large adenoma. However this is a non-progressive adenoma, so this adenoma will never transform into cancer. The second adenoma is a progressive adenoma. After having grown to 6–9 mm, the adenoma transforms into a malignant carcinoma, causing symptoms and eventually resulting in an earlier death from CRC.

Figure 2a Modeling natural history into life history

Life history without colorectal cancer

The life history without CRC and the development of the two adenomas are combined into a life history in the presence of CRC. This means that the state a person is in is the same as the state of the most advanced adenoma or carcinoma present. If he dies from CRC before he dies from other causes, his death age is adjusted accordingly. The combined life history with CRC is shown in the bottom line of figure 2a.

### MISCAN Simulation of screening

The complete simulation of an individual life history in figure 2a is in a situation without screening taking place. After the model has generated a life history with CRC but without screening, screening is overlayed. This is shown in figure 2b. The first three lines show the combined life history with CRC and the development of the two adenomas from figure 2a. At the moment of screening both adenomas are present, detected and removed. This results in a combined life history for CRC and screening (bottom line), where the person is adenoma-carcinoma free after the screening intervention. Because the precursor lesion has been removed this individual does not develop CRC and will therefore not die of CRC. The moment of death is delayed until the moment of death of other causes. The benefit of screening is equal to the difference between life-years lived in a situation with screening and the situation with screening.

Figure 2b Modeling screening into life history

Combined life history for colorectal cancer but not for screening

Many other scenarios could have occurred. A person could have developed a third adenoma after the screening moment and could still have died of CRC. Another possibility would have been that one of the adenomas was missed, but in the presented example the individual really benefited of the screening intervention.

The effectiveness of screening depends on the performance characteristics of the test performed: sensitivity, specificity and reach. In the model, one minus the specificity is defined as the probability of a positive test result in an individual irrespective of any adenomas or cancers present. For a person without any adenomas or cancers, the probability of a positive test result is therefore equal to one minus the specificity. In individuals with adenomas or cancer the probability of a positive test result is dependent on the lack of specificity and the sensitivity of the test for the present lesions. Sensitivity in the model is lesion-specific, where each adenoma or cancer contributes to the probability of a positive test result.

The model provides the opportunity to consider the possibility of systematic test results. This can be very important in the case of DNA stool screening where only a limited amount of DNA mutations can be investigated. If an adenoma or cancer occurs from a mutation different from the mutations tested for, this lesion cannot be detected by the DNA stool test and will yield a systematic negative test result. We will explore the effect of negative systematic test results as part of the sensitivity analyses.

## Appendix 2B Description of the SimCRC summary of natural history and intervention model

### SimCRC Natural History Model

The SimCRC natural history model describes the progression of underlying disease among an unscreened population. It models the transitions from normal colonic epithelium to small adenomas (defined as 1–5 mm), from small to medium adenomas (defined as 6–9mm), from medium to large adenomas (defined as ≥10 mm) or to preclinical cancer, from large adenomas to preclinical cancer (stages I-IV), and from preclinical to symptom-detected CRC. This disease process is allowed to progress separately for three segments of the CRC tract (i.e., the proximal colon, the distal colon, and the rectum) and we allow for multiple lesions per person.

The model is calibrated by simulating the life histories of cohorts of individuals under a given set of parameter values and comparing the model-predicted outcomes with observed data on the prevalence, location, size, and multiplicity of adenomas and the prevalence of preclinical cancer from autopsy studies by age and sex and the stage- and location-specific incidence of CRC by age, sex, and race from the SEER Program. We used likelihood-based goodness of fit scores to evaluate the simultaneous fit to these data and we searched the parameter space using the simulated annealing algorithm. All predictions are very close to falling within one standard error of the observed data. The best-fitting model also provides an excellent fit to the overall risk of developing CRC by age.

### SimCRC Screening Model

The natural history model has a screening component that incorporates the impact of the various FOBT technologies, flexible sigmoidoscopy, and colonoscopy. The effectiveness of each screening test is modeled through each test’s ability to detect lesions (i.e., adenomas, preclinical cancer). In the natural history model (i.e., in the absence of screening), all disease states are undetected except for the symptom-detected cancer states. Once screening is introduced, a simulated person who has an underlying adenoma or preclinical cancer has a chance of having it detected during a screening year as a function of his or her adherence rate and the sensitivity of the test. Test sensitivity can vary depending upon the size of the adenoma and the presence of a preclinical cancer. The three tests vary in terms of their test characteristics, reach, and risk. FOBT has the ability to detect a lesion in any segment of the colorectal system, but tends to have relatively poorer test characteristics compared with the other screening modalities. We model the test sensitivity for all tests as lesion-based. When a simulated person undergoes a test, each adenoma or preclinical cancer residing in the colon or rectum that is within reach has the chance of being detected, based on the lesion-specific sensitivity. We assume that colonoscopy is recommended for all persons with a positive FOBT or flexible sigmoidoscopy. For screened persons without an underlying lesion we apply the false-positive fraction (1 – specificity) to determine whether or not that person will undergo unnecessary follow-up examination. We also incorporate the chance of sending a person to colonoscopy with only hyperplastic polyps. Hyperplastic polyps are not modeled explicitly but are reflected in the specificity of the test. In addition, a percentage of false-negative patients (i.e., adenoma or preclinical cancer present but not detected by sigmoidoscopy) will be referred to colonoscopy because of the detection of a hyperplastic polyp. Colonoscopy is associated with a small mortality risk due to the risk of perforations during the procedure.