# Summary of recent literature review on DNA stool test and FIT

Table A.1.1 Test characteristics for DNA stool test (version 1.0) followed by colonoscopy for all

| | | Sensitivity, %
Author, Year Journal | N in study | Country, year | CRC | CRC or high-grade dysplasia | Aden ≥1.0 cm, villous, HGD) | Aden < 1 cm | Specificity (no polyps), %
Imperiale, 2004 N Engl J Med^*^ | 2,507 | US | 51.6 (34.8–68.0) | 40.8 (30.2–52.5) | 15.1 (12.0–19.0) | 8.0 (5.9–12.7) | 94.4 (93.1–95.5)
Ahlquist, in progress MAYO-MC9944 NCI P930-CA15083^†^ | 4,000 to be enrolled | US
Ahlquist, 2005 abstract NCI U10-CA8938^‡^ | 2,502 average for 2005 | US | | | | | 96.0

* Asymptomatic average risk population, with family history of 14%. Test with 22 markers plus DNA integrity (pre commercial version 1.0), compared with Hemoccult II.

† RCT of no red meat, NSAIDS, vitamin C, or multivitamins versus no vitamin C or multivitamin 3 days before DNA stool sample.

‡ Study design similar to Imperiale; to be completed in 2007. RCT of FOBT and multitarget DNA-based assay panel testing followed by colonoscopy in the detection of CRC. Project began June, 2001 and ended August, 2007 (information from CRISP (1/23/2007).

Table A.1.2 Test characteristics for PreGen-Plus (version 1.1)

| | | Sensitivity, %>
Author, Year Journal | N in study | Country, year | CRC | CRC or high-grade dysplasia | Aden ≥1.0 cm) | Aden <1 cm | Specificity (no polyps), %
Ahlquist, 2007 abstracts NCI U10-CA8938^*^ | 4010 subjects 218 with sDNA | US, 2007 | | | | | 84.0
Whitney, 2004§ J Mol Diagn | 86 CRC, 100 col neg pts | US, 2004 | 70.0 (59.0–79.0) | | | | 96.0 (91.5–99.4)
Itzkowitz, 2007 Clin Gastroenterol^†^ | 40 CRC, 122 col neg pts | US, 2007 | 72.5 (57.2–83.9) | | | | 89.3 (82.6–93.7)

* Study design similar to Imperiale; to be completed in 2007. RCT of FOBT and multitarget DNA-based assay panel testing followed by colonoscopy in the detection of CRC. Project began June, 2001 and ended August, 2007 (information from CRISP (1/23/2007).

† Archived stool samples from CRC and colonoscopy negative patients. Same Itzkowitz study of 40 CRC and 122 colonoscopy negative patients as reported for version 2.0. The updated version 1.1 assay was conducted on the stool samples of these patients.

Table A.1.3 Test characteristics for DNA stool test (version 1.0) preselected colorectal cancer and controls

| | | Sensitivity, %
Author, Year Journal | N in study | Country, year | CRC | CRC or high-grade dysplasia | Aden ≥1.0 cm, villous, HGD) | Aden <1 cm | Specificity (no polyps), %
Ahlquist, 2000 Gastroenterology | 22 CRC, 11 aden>1 cm, 28 no polyps | US | 91.0 | | 82.0 (48.0–98.0) | | 93.0
Tagore, 2003 Clin Colorectal Cancer | 52 CRC. 28 adv aden, 113 neg col, 99 minor pol | US | 63.5 (49.0–76.4) Stg I 75.0 Stg II 67.0 | | 57.1 (37.2–75.5) HGD 86.0 lrg ad 48.0 | 6.1 (2.3–12.7) | 96.8 (92.7–98.4)
Calistri, 2003 Gastroenterology | 56 CRC 38 healthy | | 62.0 | | | | 97
Brand, 2004 Am J Gastroenterol | 16 CRC | US | 69
Syngal, 2006 Cancer | 68 CRC, 23 adv aden | US, 09/2001–04/2003 | 63 Stage I 39% Stage II,III, IV 72% | 54 | 26 (10–48) HGD 33

Table A.1.4 Test characteristics for DNA stool test (potential version 2.0) selected colorectal cancer and controls

| | | Sensitivity, %
Author, Year Journal | N in study | Country, year | CRC | CRC or high-grade dysplasia | Aden ≥1.0 cm, villous, HGD) | Aden <1 cm | Specificity (no polyps), %
Itzkowitz, 2007^*^ Clin Gastroenterol Hepatol | 40 CRC, 122 no polyps | US | 87.5 (73.9–94.5) | | | | 82.0 (74.2–87.8)

* Post-colonoscopy DNA stool samples in all CRC and sample of no polyps. Training set analysis without validation study. First set of sensitivities for modified version 1.0; second set for version 2.0 with 2 markers as noted here.

Table A.1.5 Fecal immunochemical test (FIT) followed by colonoscopy for all – updates beyond 2003 FIT report

| | | Sensitivity, %
Author, Year Journal | N in study | Country, year | CRC | CRC or high-grade dysplasia | Aden ≥1.0 cm, villous, HGD) | Aden < 1 cm | Specificity (no polyps), %
Morikawa, 2005^*^ Gastroenterology | 21,805 | Japan, 1983– 2002 | 65.8 (55.4–76.3) | 27.1 (23.9–30.3) (just HGD) | 20.0 aden≥1 cm 33.0 HGD | See below | 95.5 (95.2–95.8)
Morikawa 2007^*^ Am J Gastroenterology | Same study as above | Japan 1983– 2002 | As above | | As above | 7% | As above
Levi, 2007^†^ Ann Intern Med (Updates Vilkin 2005 Am J Gastroenterology) | 1,000 | Israel | 75-ng/mL threshold 94.0 (82.9–100) | 67% (57.4–76.7) | | | 87.5 (85.4–89.6 for CC and 91.4 (89.6–93.2) for crc or adv adenoma

* Magstream 1000/Hem SP, average-risk population having comprehensive health exam with FIT and then colonoscopy during 1983–2002. Sensitivity is higher for high-grade dysplasia (HGD) than for larger adenoma. One day test.

† Three-day samples using two thresholds 75 and 100 ng/mL, where 100 ng/mL is the manufacturer-recommended level. High-risk population. Average fecal hemoglobin levels used in comparing groups. .Japanese FIT was used.

Table A.1.6 Fecal immunochemical test (FIT) – updates beyond 2003 FIT report

| | | Sensitivity, %
Author, Year Journal | N in study | Country, year | CRC | CRC or high-grade dysplasia | Aden ≥1.0 cm, villous, HG) | Aden < 1 cm | Specificity (no polyps), %
Guittet, 2007^*^ Gut | 10,804 | France, 2004– 2005 | 76 | 53 | 50 | 17 | 97
Fraser, 2006^†^ Lancet Oncol | 795 | Scotland ‘04-‘05 | 95 | 90.1
Smith, 2006^‡^ Cancer | 2351 screening cohort and 161 symptomatic | Australia 2002– 2004 | 87.5 92.3 for Stage I. | 55 | 43 | 28 | 97
Allison 2007^§^ J Natl Cancer Inst | 5841 Kaiser Permanente | California 1997– 1999 | 81.8 (47.8–96.8) | | 29.5 21.4–48.9 | | 98

* Screening program for ages 50–74 with Immudia/RPHA FIT (Magstream 100/Hem SP, with Hemoccult II as comparator. Colonoscopy for positive on either test – 20% of positives did not get colonoscopy. Used Schatzkin’s ratios of sensitivities and ratio of false positive rates.

† Guaiac Hemascreen positive results given FIT and then colonoscopy.

‡ Enterix-InSure vs. Hemoccult SENSA. Screening 2000–2004 for high risk. Diagnostic cohort April 2002–Sept 2003.

§ FlexSure OBT

Table A.1.7 FIT compared with guaiac FOBT – updates for guaiac FOBT beyond 2003 FIT report

| | | Sensitivity, %
Author, Year Journal | N in study | Country, year | CRC | CRC or high-grade dysplasia | Aden ≥1.0 cm, villous, HG) | Aden < 1 cm | Specificity (no polyps), %
Guittet, 2007^*^ Gut | 10,804 | France, 2004– 2005 | 67 | 31 | 26 | 24 | 99.9
Smith, 2006^†^ Cancer | 2,351 screening cohort and 161 symptomatic | Australia 2002– 2004 screening | 54 31 for Stage I | 32 | 23 | 26 | 97.5
Allison 2007^‡^ J Natl Cancer Inst | 5841 Kaiser Permanente | California 1997– 1999 | 64.3 35.6–86.0 | | 41.3 32.7–50.4 | | 98

* Screening program for ages 50–74, with Magstream 100/Hem SP as comparator. Colonoscopy for positive on either test – 20% of positives did not get colonoscopy. Used Schatzkin’s ratios of sensitivities and ratio of false positive rates.

† Enterix vs Hemoccult SENSA

‡ Hemoccult SENS compared with FlexSure OBT at Kaiser Permanente

## Appendix tables from the immunochemical fecal occult blood test cost-effectiveness report to CMS (van Ballegooijen 2003), with updated literature

Table Appendix 1.A Guaiac Hemoccult II (un-rehydrated and rehydrated) – from FIT report, 2003

Author, Year Journal | N in Study | Country | Sensitivity CRC, % | Sensitivity large aden, % | Spec, %
Studies with colonoscopy follow-up and negative tests with surveillance of at least one year
Hemoccult II un-reydrated
Allison, 1996 N Engl J Med | 8,065 | US | 37.1 | 30.1 | 98.1
Petrelli, 1994 Surg Oncol | 8,933 | US | 37.1 | -- | 98.1
Robinson, 1994 Br J Surg | 1,489 | UK | 11.1 | -- | 98.9
Hemoccult II rehydrated
Castiglione, 1996 Br J Cancer | 8,008 | Italy | 68.2 | 52.9 | 94.1
Randomized controlled trials
Hemoccult II un-rehydrated
Mandel, 1993 N Engl J Med | 45,000 | US | 80.8 | -- | 97.7
Hardcastle, 1996 Lancet | 150,000 | UK | 58.6 | -- | 96.8
Kronberg, 1996 Lancet | 60,000 | Denmark | 55.5 | -- | 99.3
Gyrd-Hansen, 1997 Int J Epidemiol | 60,000 | Denmark | 62.1 | -- | --
Hemoccult II rehydrated
Mandel, 1993 N Engl J Med | 45,000 | US | 92.2 | -- | 90.4
Church, 1997 JNCI | 45,000 | US | 90 | -- | --
Studies with FOBT followed by colonoscopy for all
Hemoccult II un-rehydrated
Greenberg, 2000 Am J Gastroenterol | 554 | 9 centers in world | 85.7 | 20.5 | 92.8
Zauber, 2002 Gastroenterology | 881 | US | -- | 23 | 91
Hemoccult II rehydrated
Lieberman, 2001 N Engl J Med | 2,885 | US | 50 | 21.6^*^ | 93.8

* Sensitivity for small adenoma = 7.0%.

Table Appendix 1.B Guaiac Hemoccult SENSA – from FIT report, 2003

Author, Year Journal | N in Study | Country | Sensitivity CRC, % | Sensitivity large aden, % | Spec, %
Studies with colonoscopy follow-up and negative tests with or without surveillance of at least one year
Allison, 1996 N Engl J Med | 8,065 | US | 79.4 | 68.6 | 87.5
Cole, 2003 Gastroenterology | 460 | Australia | 38.5 | -- | --
Studies with FOBT followed by colonoscopy for all
Greenberg, 2000 Am J Gastroenterol | 554 | 9 centers in world | 78.6 | 35.9 | 90.5

Table Appendix 1.C Immunochemical FOBT – from FIT report, 2003

Author, Year Journal | N in Study | Country | Sensitivity CRC, % | Sensitivity large aden, % | Spec, %
Studies with colonoscopy follow-up and negative tests with surveillance of at least one year
HemeSelect
Allison, 1996 N Engl J Med | 8,065 | US | 68.8 | 66.7 | 95.2
Robinson, 1994 Br J Surg | 1,489 | UK | 100 | -- | 90.8 (94.9)
Castiglione, 1996 Br J Cancer | 8,008 | Italy | 95.5 | 78.6 | 92.0 (92.7)
Monhaem
Nakama, 1994 Prev Med | 3,365 | Japan | 91 | -- | 96.0
Nakama, 1994 Prev Med | 3,365 | Japan | 71.4 | -- | 95.6
Nakama, 1999 Hepatol-Gastro | 4,611 | Japan | 88.9 | -- | 93.1
Insure
Cole, 2003 Gastroenterol | 460 | Australia | 85 | -- | --
Randomized control trials
None
Studies with FOBT followed by colonoscopy or flexible sigmoidoscopy for all
Flexsure
Young, 2003 J Med Screen | | Australia | 80 | -- | 97.2
Greenberg, 2000 Am J Gastro | 554 | World | 87.5 | -- | 86.2
HemeSelect
Allison, 2002 Gastroenterology | 5356 | US | 81.8* | 25.4 | 97.5
Greenberg, 2000 Am J Gastro | 554 | World | 83.3 | -- | 88.2
Nakama, 1999 HepGastro | 4611 | Japan | 83.3 | 50.7 | 96
Magstream 1000/Hem SP
Wong, 2003 Cancer | 250 | China | 62 | 47 | 93
Insure
Young, 2003 J Med Screen | | Australia | 75 | -- | 97.8

Table Appendix 1.D Package inserts

Company, Year | Country | Sens CRC, % | Sens large aden % | Sens small aden % | Spec %
Hemoccult II un-rehydrated
Beckman-Coulter, 2000 | US | 86 | 53 | 32 | 98
Hemoccult SENSA
Beckman-Coulter, 2000 | US | 92 | 67 | 43 | 96.5
Immunochemical Test Insure
Enterix, 2003 | US | 87 | 47.4 | -- | 97.7

Table Appendix 1.E Estimates from cost-effectiveness assumptions and guidelines

Author, Year Journal | Sensitivity CRC % | Sensitivity large aden % | Sensitivity small aden % | Spec, %
Cost-Effectiveness Models
Hemoccult II un-rehydrated
Frazier, 2000 JAMA | 33 | -- | 2 | 97
Loeve, 1999 Comput Biomed Res | 60 | 5 | 2 | 98
Sonnenberg, 2000 Ann Intern Med | 40 | -- | -- | 97.5
Wagner, 1996 Prev | 60 | -- | -- | 90
Hemoccult II rehydrated
Frazier, 2000 JAMA | 60 | -- | -- | 90
Loeve, 1999 Comput Biomed Res | 70 | 20 | -- | 90
Khandker, 2000 Int J Tech Assess | 60 | 10 | 6 | 92
Guidelines Recommendations
Hemoccult II un-rehydrated
Winawer, 1997 Gastroenterology | 60 | -- | -- | 90
Australian, 1997 Austral Health Tech | 50 | 10 | -- | 92

Table F Studies comparing multiple FOBTs

Author, Year | Hemoccult II unrehydrated | Hemoccult II rehydrated | Hemoccult SENSA | Immunochemical | Fecal DNA
Allison, 1996 | X | | X | HemeSelect
Allison. 2002 | | | X | HemeSelect or FlexSure
Castilgone, 1996 | | X | | HemeSelect (1 day + and +/−)
Robinson, 1994 | X | | | Hemeselect 3 day
Greenberg, 2000 | X | | X | HemeSelect and FlexSure
Young, 2003 | | | | InSure and FlexSure
Cole, 2003 | | | X | InSure
Guittet, 2007 | X | | | Magstream 1000/Hem SP
Allison, 2007 | | | X | FlexSureOBT
Alqhuist, 2007 | X | | X | | X
Imperiale, 2004 | X | | | | X

## Additional references for Appendix from van Ballegooijen (2003) on immunochemical FOBT cost effectiveness analysis (not included in main reference section)

Allison JE, Tekawa IS, Ransom LJ, Adrain AL. A comparison of fecal-occult blood tests for colorectal-cancer screening. N Engl J Med. 1996;334:155-159. [pmid: 8531970].
Allison JE, Levin T Sakoda L, Tucker J, Tekawa I, Pauly MP et al. The new fecal occult blood tests have poor application sensitivity for significant polyps in average risk subjects. Gastroenterology. 2002:A-592.
Australian Health Technology Advisory Committee. Colorectal cancer screening. 1997. Dec.
Castiglione G, Zappa M, Grazzini G, Mazzotta A, Biagini M, Salvadori P, Ciatto S. Immunochemical vs guaiac faecal occult blood tests in a population-based screening programme for colorectal cancer. Br J Cancer. 1996;74:141-144. [pmid: 8679448].
Church TR, Ederer F, Mandel JS. Fecal occult blood screening in the Minnesota Study: sensitivity of the screening test. J Natl Cancer Inst. 1997;89:1440-1448. [pmid: 9326913].
Cole S, Smith A, Bampton P, Sandford J, Morcom J, Young GP. Screening for colorectal cancer: direct comparison of a brush-sampling fecal immunochemical tests for hemoglobin with Hemoccult SENSA. Gastroenterology. 2003;124:A631.
Greenberg PD, Bertario L, Gnauck R, Kronborg O, Hardcastle JD, Epstein MS, Sadowski D, Sudduth R, Zuckerman GR, Rockey DC. A prospective multicenter evaluation of new fecal occult blood tests in patients undergoing colonoscopy. Am J Gastroenterol. 2000;95:1331-1338. [pmid: 10811348].
Guittet L, Bouvier V, Mariotte N, Vallee JP, Arsene D, Boutreux S, Tichet J, Launoy G. Comparison of a guaiac based and an immunochemical faecal occult blood test in screening for colorectal cancer in a general average risk population. Gut. 2007;56:210-214. [pmid: 16891354].
Hardcastle JD, Thomas WM, Chamberlain J, et al. Randomised, controlled trial of faecal occult blood screening for colorectal cancer. Results for first 107,349 subjects. Lancet. 1989;1:1160-1164. [pmid: 2566735].
Khandker RK, Dulski JD, Kilpatrick JB, Ellis RP, Mitchell JB, Baine WB. A decision model and cost-effectiveness analysis of colorectal cancer screening and surveillance guidelines for average-risk adults. Int J Technology Assessment in Health Care. 2000;16:799-810.
Lieberman DA, Weiss DG. for the VA Cooperative Study Group. One-time screening for colorectal cancer with combined fecal occult-blood testing and examination of the distal colon. N Engl J Med. 2001;345:555-560. [pmid: 11529208].
Nakama H, Kamijo N. Accuracy of immunological fecal occult blood testing for colorectal cancer screening. Prev Med. 1994;23:309-313. [pmid: 8078851].
Nakama H, Yamamoto M, Kamijo N, Li T, Wei N, Fattah AS, Zhang B. Colonoscopic evaluation of immunochemical fecal occult blood test for detection of colorectal neoplasia. Hepatol-Gastroenterology. 1999;46:228-231.
Petrelli N, Michalek AM, Freedman A, Baroni M, Mink I, Rodriguez-Bigas M. Immunochemical versus guaiac occult blood stool tests: results of a community-based screening program. Surg Oncol. 1994;3:27-36. [pmid: 8186868].
Robinson MHE, Marks CG, Farrands PA et al. Population screening for colorectal cancer: comparison between guaiac and immunological faecal occult blood tests. Br J Surg. 1994;81:448-451. [pmid: 8173928].
Sonnenberg A, Delco F, Inadomi JM. Cost-effectiveness of colonoscopy in screening for colorectal cancer. Ann Intern Med. 2000;133:573-584. [pmid: 11033584].
Wagner JL, Tunis S, Brown M, Ching A, Almeida R. Young GP, Rozen P, Levin B, editors. Cost-effectiveness of colorectal cancer: screening in average risk adults. Prevention and Early Detection of Colorectal Cancer. London. WB Saunders. 1996.
Wong WM, Lam SK, Cheung KL, Tong TSM, Rozen P, Young GP, et al. Evaluation of an automated immunochemical fecal occult blood tests for colorectal neoplasia detection in a Chinese population. Cancer. 2003;97:2420-2424. [pmid: 12733140].
Young GP, St John DJ, Cole SR, Bielecki BE, Pizzey C, Sinatra MA, Polglase AL, Cadd B, Morcom J. Prescreening evaluation of a brush-based faecal immunochemical test for haemoglobin. J Med Screen. 2003;10:123-128. [pmid: 14561263].
Zauber AG, Winawer SJ, Bond JH, Waye JD, Schapiro M, O’Brien MJ, Sternberg S. National Polyp Study Workgroup. FOBT is of limited value in post-polypectomy colonoscopy surveillance. Gastroenterology. Suppl. 2002;122:A486.