# Abbreviations that appear in the report

ACER: Average cost-effectiveness ratio
AHRQ: Agency for Healthcare Research and Quality
ASC: Ambulatory surgery center
CISNET: Cancer Intervention and Surveillance Modeling Network
CMS: Centers for Medicare and Medicaid Services
COL: Colonoscopy
CPT: Current procedural terminology
CRC: Colorectal cancer
DIA®: DNA Integrity Assay
DRG: Diagnosis-related group
FIT: Fecal immunochemical test or immunochemical FOBT (iFOBT)
FOBT: Fecal occult blood test
HII: Hemoccult II®, a guaiac-based FOBT
HS: Hemoccult SENSA®, a guaiac-based FOBT
ICER: Incremental cost-effectiveness ratio
IPPS: Inpatient prospective payment system
MISCAN: Microsimulation model of Memorial Sloan-Kettering Cancer Center and ErasmusMC
NCD: National coverage determination
NCI: National Cancer Institute
OPPS: Outpatient prospective payment system
PFS: Physician fee schedule
sDNA: DNA stool test
SEER: Surveillance, Epidemiology, and End Results
SIG: Flexible sigmoidoscopy
SimCRC: Microsimulation model of University of Minnesota and Massachusetts General Hospital
TEC: Technology Evaluation Center
USPSTF: United States Preventive Services Task Force