# REFERENCES

Adam IJ, Ali Z, Shorthouse AJ. How accurate is the endoscopist’s assessment of visualization of the left colon seen at flexible sigmoidoscopy?. Colorectal Dis. 2000;2:1-44. [pmid: 23577926].
Ahlquist DA, Skoletsky JE, Boynton KA, Harrington JJ, Mahoney DW, Pierceall WE, Thibodeau SN, Shuber AP. Colorectal cancer screening by detection of altered human DNA in stool: feasibility of a multitarget assay panel. Gastroenterology. 2000;119:1219-1227. [pmid: 11054379].
Ahlquist DA, Sargent DJ, Levin TR, Rex DK, Ahnen DJ, Knigge K, Lance MP, Loprinzi CL, Burgart LJ, Allison JE, Lawson MJ, Millholland JM, Harrington JJ, Hillman SL, Devens ME. Stool DNA screening for colorectal neoplasia: prospective multicenter comparison with occult blood testing. Gastroenterology. 2005;128(S2):A-63-A-424.
Ahlquist DA, Sargent DJ, Levin TR, et al. Stool DNA screening for colorectal neoplasia: prospective multicenter comparison with occult blood testing. Gastroenterology. 2007;132((4,S1):A19.
Allison JE, Sakoda LC, Levin TR, Tucker JP, Tekawa IS, Cuff T, Pauly MP, Shlager L, Palitz AM, Zhao WK, Schwartz JS, Ransohoff DF, Selby JV. Screening for colorectal neoplasms with new fecal occult blood tests: update on performance characteristics. J Natl Cancer Inst. 2007;99:1462-1470. [pmid: 17895475].
Arminski TC, McLean DW. Incidence and distribution of adenomatous polyps of the colon and rectum based on 1,000 autopsy examinations. Dis Colon Rectum. 1964;7:249-261. [pmid: 14176135].
Atkin WS, Edwards R, Wardle J, Northover JMA, Sutton S, Hart AR, Williams CB, Cuzick J. Design of a multicentre randomised trial to evaluate flexible sigmoidoscopy in colorectal cancer screening. J Med Screen. 2001;8:137-144. [pmid: 11678553].
American Cancer Society. Cancer Facts & Figures 2007. Atlanta. American Cancer Society. 2007.
Blatt LJ. Polyps of the colon and rectum: incidence and distribution. Dis Colon Rectum. 1961;4:277-282.
Bombi JA. Polyps of the colon in Barcelona, Spain. Cancer. 1988;61:1472-1476. [pmid: 3345499].
Brand RE, Ross ME, Shuber AP. Reproducibility of a multitarget stool-based DNA assay for colorectal cancer detection. Am J Gastroenterol. 2004;99:1338-1341. [pmid: 15233675].
Brown ML, Riley GF, Potosky AL, Etzioni RD. Obtaining long-term disease specific costs of care: application to Medicare enrollees diagnosed with colorectal cancer. Med Care. 1999;37:1249-1259. [pmid: 10599606].
Calistri D, Rengucci C, Bocchini R, Saragoni L, Zoli W, Amadori D. Fecal multiple molecular tests to detect colorectal cancer in stool. Clin Gastroenterol Hepatol. 2003;1:377-383. [pmid: 15017656].
Chapman I. Adenomatous polypi of large intestine: incidence and distribution. Ann Surg. 1963;157:223-226. [pmid: 14020146].
Chen WD, Han ZJ, Skoletsky J, Olson J, Sah J, Myeroff L, Platzer P, Lu S, Dawson D, Willis J, Pretlow TP, Lutterbaugh J, Kasturi L, Willson JKV, Rao JS, Shuber A, Markowitz SD. Detection in fecal DNA of colon cancer – specific methylation of the nonexpressed vimentin gene. J Natl Cancer Inst. 2005;97:1124-1132. [pmid: 16077070].
Clark JC, Collan Y, Eide TJ, Esteve J, Ewen S, Gibbs NM, Jensen OM, Koskela E, MacLennan R, Simpson JG, Stalsberg H, Zaridze DG. Prevalence of polyps in an autopsy series from areas with varying incidence of large-bowel cancer. Int J Cancer. 1985;36:179-186. [pmid: 4018911].
Coups EJ, Manne SL, Meropol NJ, Weinberg DS. Multiple behavioral risk factors for colorectal cancer and colorectal cancer screening status. Cancer Epidemiol Biomarkers Prev. 2007;16:510-516. [pmid: 17372246].
Doria-Rose VP, Levin TR, Selby JV, Newcomb PA, Richert-Boe KE, Weiss NS. The incidence of colorectal cancer following a negative screening sigmoidoscopy: implications for screening interval. Gastroenterology. 2004;127:714-722. [pmid: 15362026].
Eide TJ, Stalsberg H. Polyps of the large intestine in northern Norway. Cancer. 1978;42:2839-2848. [pmid: 728878].
Fearon ER, Vogelstein B. A genetic model for colorectal tumorigenesis. Cell. 1990;61:759-767. [pmid: 2188735].
Frazier AL, Colditz GA, Fuchs CS, Kuntz KM. Cost-effectiveness of screening for colorectal cancer in the general population. JAMA. 2000;284:1854-1961.
Gold MR, Siegel JE, Russel LB, Weinstein MC, editors. Cost-effectiveness in Health and Medicine. New York (NY). Oxford University Press. 1996.
Gyrd-Hansen D, Sogaard J, Kronborg O. Analysis of screening data: colorectal cancer. Int J Epidemiol. 1997;26:1172-1181. [pmid: 9447396].
Hardcastle JD, Chamberlain JO, Robinson MH, et al. Randomised controlled trial of faecal-occult-blood screening for colorectal cancer. Lancet. 1996;348:1472-1477. [pmid: 8942775].
Imperiale TF, Ransohoff DF, Itzkowitz SH, Turnbull BA, Ross ME. for the Colorectal Cancer Study Group. Fecal DNA versus fecal occult blood for colorectal-cancer screening in an average-risk population. N Engl J Med. 2004;351:2704-2714. [pmid: 15616205].
Itzkowitz SH, Jandorf L, Brand R, Rabeneck L, Schroy PC 3rd, Sontag S, Johnson D, Skoletsky J, Durkee K, Markowitz S, Shuber A. Improved fecal DNA test for colorectal cancer screening. Clin Gastroenterol Hepatol. 2007;5:111-117. [pmid: 17161655].
Jass JR, Young PJ, Robinson EM. Predictors of presence, multiplicity, size and dysplasia of colorectal adenomas. A necropsy study in New Zealand. Gut. 1992;33:1508-1514. [pmid: 1452076].
Jentschura D, Raute M, Winter J, Hendel T, Kraus M, Manegold BC. Complications in endoscopy of the lower gastrointestinal tract. Therapy and prognosis. Surg Endosc. 1994;8:672-676. [pmid: 8059305].
Johannsen LGK, Momsen O, Jacobsen NO. Polyps of the large intestine in Aarhus, Demark. An autopsy study. Scand J Gastroenterol. 1989;24:799-806. [pmid: 2799283].
Klabunde C, Warren J, Ransohoff DF, Brown ML. Complications of colonoscopy in the Medicare population. Gastroenterology. Supplement 2. 2007;132::A149. (995).
Kronborg O, Fenger C, Olsen J, Jorgensen OD, Sondergaard O. Randomised study of screening for colorectal cancer with faecal-occult-blood test. Lancet. 1996;348:1467-1471. [pmid: 8942774].
Knudsen AB, Wang YC, Weinstein MC, Weeks JC, Kuntz KM. Explaining the secular trends in colorectal cancer incidence and mortality using a population-based microsimulation model [Abstract]. Med Decis Making. 2004:24.
Knudsen AB. Explaining secular trends in colorectal cancer incidence and mortality with an empirically-calibrated microsimulation model [Ph.D. dissertation]. Cambridge, MA. Harvard University. 2005.
Lieberman DA, Weiss DG, Bond JH, Ahnen DF, Garewal H, Chejfec G. Use of colonoscopy to screen asymptomatic adults for colorectal cancer. Veterans Affairs Cooperative Study Group 380. N Engl J Med. 2000;343:162-168. [pmid: 10900274].
Levin TR, Conell C, Shapiro JA, Chazan SG, Nadel Mr, Selby JV. Complications of screening flexible sigmoidoscopy. Gastroenterology. 2002;123:1786-1792. [pmid: 12454834].
Levin TR, Zhao W, Connell C, Seeff LC, Manninen Dl, Shapiro JA, Shulman J. Complications of colonoscopy in an integrated health care delivery system. Ann Intern Med. 2006;1145:880-886. [pmid: 17179057].
Loeve F, Boer R, van Oortmarssen GJ, van Ballegooijen M, Habbema JD. The MISCAN-COLON simulation model for the evaluation of colorectal cancer screening. Comput Biomed Res. 1999;32:13-33. [pmid: 10066353].
Loeve F, Brown ML, Boer R, van Ballegooijen M, van Oortmarssen GJ, Habbema JD. Endoscopic colorectal cancer screening: a cost-saving analysis. J Natl Cancer Inst. 2000;92:557-563. [pmid: 10749911].
Mandel JS, Bond JH, Church TR, et al. Reducing mortality from colorectal cancer by screening for fecal occult blood. Minnesota Colon Cancer Control Study. N Engl J Med. 1993;328:1365-1371. [pmid: 8474513].
Mandel JS, Church TR, Ederer F, Bond JH. Colorectal cancer mortality: effectiveness of biennial screening for fecal occult blood. J Natl Cancer Inst. 1999;91:434-437. [pmid: 10070942].
Mandel JS, Church TR, Bond JH. The effect of fecal occult-blood screening on the incidence of colorectal cancer. N Engl J Med. 2000;343:1603-1607. [pmid: 11096167].
Morson B. The pathogenesis of colorectal cancer. Introduction. MajorProbl Pathol. 1978;10:1-13.
Morikawa T, Kato J, Yamaji Y, Wada R, Mitsushima T, Shiratori Y. A comparison of the immunochemical fecal occult blood test and total colonoscopy in the asymptomatic population. Gastroenterology. 2005;129:422-428. [pmid: 16083699].
Morikawa T, Kato J, Yamaji Y, Wada R, Mitsushima T, Sakaguchi K, Shiratori Y. Sensitivity of immunochemical fecal occult blood test to small colorectal adenomas. Am J Gastroenterol. 2007;102:2259-2264. [pmid: 17617203].
O’Brien MJ, Winawer SJ, Zauber AG, Gottlieb LS, Sternberg SS, Diaz B, Dickersin R, Ewing S, Geller S, Dasimian D, Komorowski R, Szporn A. National Polyp Study Workgroup. The National Polyp Study: Patient and polyp characteristics associated with high-grade dysplasia in colorectal adenomas. Gastroenterolgy. 1990;98:371-379.
Olson J, Whitney DH, Durkeee K, Shuber AP. DNA stabilization is critical for maximizing performance of fecal DNA-based colorectal cancer tests. Diagn Mol Pathol. 2005;14. 1893-191.
Parekh M, Fendrick M, Ladabaum U. Reappraisal of fecal DNA testing in light of evolving test performance characteristics and increasing colorectal cancer treatment costs. Gastroenterology. 2006:A-471.
Perrone M. Government officials will consider paying for Exact Sciences colon cancer screening test. Associated Press Financial Wire, Business News; 08/02/2007.
Pignone M, Rich M, Teutsch SM, Berg AO, Lohr KN. Screening for colorectal cancer in adults at average risk: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137:132-141. [pmid: 12118972].
Pignone M, Saha S, Hoerger T, Mandelblatt J. Cost-effectiveness analyses of colorectal cancer screening: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2002;137:96-104. [pmid: 12118964].
Pox C, Schmiegel W, Classen M. Current status of screening colonoscopy in Europe and in the United States. Endoscopy. 2007;39:168-173. [pmid: 17327977].
Prorok PC, Andriole GL, Bresalier RS, Buys SS, Chia D, Crawford ED, Fogel R, Gelmann EP, Gilbert F, Hasson MA, Hayes RB, Johnson CC, Mandel JS, Oberman A, O’Brien B, Oken MM, Rafla S, Reding D, Rutt W, Weissfeld JL, Yokochi L, Gohagan JK. Prostate, Lung, Colorectal and Ovarian Cancer Screening Trial Project Team. Design of the Prostate, Lung, Colorectal and Ovarian (PLCO) Cancer Screening Trial. Controlled Clinical Trials. Suppl 6. 2000;21:273S-309S. [pmid: 11189684].
Ransohoff DF, Lang CA. Improving the fecal occult blood test. N Engl J Med. 1996;334:189-190. [pmid: 8531978].
Regula J, Rupinski M, Kraszewska E, Polkowski M, Pachlewski J, Orlowska J, Nowacki MP, Butruk E. Colonoscopy in colorectal-cancer screening for detection of advanced neoplasia. N Engl J Med. 2006;355:1863-1872. [pmid: 17079760].
Rex DK, Kahi CJ, Levin B, Smith RA, Bond JH, Brooks D, Burt RW, Byers T, Fletcher RH, Hyman N, Johnson D, Kirk L, Lieberman DA, Levin TR, O’Brien MJ, Simmang C, Thorson AG, Winawer SJ. Guidelines for colonoscopy surveillance after cancer resection: a consensus update by the American Cancer Society and US Multi-Society Task Force on Colorectal Cancer. Gastroenterology. 2006;130:1865-1871. [pmid: 16697749].
Rickert RR, Auerbach O, Garfinkel L, Hammond EC, Frasca JM. Adenomatous lesions of the large bowel. An autopsy survey. Cancer. 1979;43:1847-1857. [pmid: 445371].
Ries LAG, Melbert D, Krapcho M, Mariotto A, Miller BA, Feuer EJ, Clegg L, Horner MJ, Howlader N, Eisner MP, Reichman M, Edwards BK, editors. SEER Cancer Statistics Review, 1975–2004. Bethesda, MD. National Cancer Institute. 2007. http://seer.cancer.gov/csr/1975_2004/, based on November 2006 SEER data submission, posted to the SEER web site,.
Schrag D. The price tag on progress-chemotherapy for colorectal cancer. N Engl J Med. 2004;351:317-319. [pmid: 15269308].
Schroy PC III, Heeren TC. Patient perceptions of stool-based DNA testing for colorectal cancer screening. Am J Pre Med. 2005;28:208-214.
Schroy PC III, Lai S, Glick JT, Robinson PA, Zamor P, Heeren TC. Patient preferences for colorectal cancer screening: how does stool DNA testing fare?. Am J Manag Care. 2007;13:393-400. [pmid: 17620034].
Segnan N, Senore C, Andreoni B, Aste H, Bonelli L, Crosta C, Ferraris R, Gasperoni S, Penna A, Risio M, Rossini FP, Sciallero S, Zappa M, Atkin WS. the SCORE Working Group – Italy. Baseline findings of the Italian multicenter randomized controlled trial of “once-only sigmoidoscopy”–SCORE. J Natl Cancer Inst. 2002;94:1763-1772. [pmid: 12464648].
Selby JV, Friedman GD, Quesenberry CPJ, Weiss NS. A case-control study of screening sigmoidoscopy and mortality from colorectal cancer. N Engl J Med. 1992;326:653-657. [pmid: 1736103].
Seeff LC, Richards TB, Shapiro JA, et al. How many endoscopies are performed for colorectal cancer screening? Results from CDC’s survey of endoscopic capacity. Gastroenterolgoy. 2004;127:1670-1677.
Smith RA, Cokkinides V, Eyre HJ. American Cancer Society Guidelines for the early detection of cancer, 2006. CA Cancer J Clin. 2006;56:11-25. [pmid: 16449183].
Song K, Fendrick AM, Ladabaum R. Fecal DNA compared with conventional colorectal methods: a decision analysis. Gastroenterology. 2004;126:1270-1279. [pmid: 15131787].
Surveillance, Epidemiology, and End Results (SEER) Program. (http://www.seer.cancer.gov) SEER*Stat Database: Incidence – SEER 9 Regs Public-Use, Nov 2003 Sub (1973–2001), National Cancer Institute, DCCPS, Surveillance Research Program, Cancer Statistics Branch, released April 2004, based on the November 2003 submission.
Syngal S, Stoffel E, Chung D, Willett C, Schoetz D, Schroy P, Jagadeesh D, Morel K, Ross M. Detection of stool DNA mutations before and after treatment of colorectal neoplasia. Cancer. 2006;106:277-283. [pmid: 16342248].
Tagore KS, Lawson MJ, Yucaitis JA, Gage R, Orr T, Shuber AP, Ross ME. Sensitivity and specificity of a stool multitarget assay panel for the detection of advanced colorectal neoplasia. Clin Colorectal Cancer. 2003;3:47-53. [pmid: 12777192].
Technology Evaluation Center. Special Report: Fecal DNA analysis for colon cancer screening. Assessment Program. August. 2006;Volume 21(No. 6). Lead author Piper MA.
U.S. Preventive Services Task Force. Screening for colorectal cancer: recommendation and rationale. Ann Intern Med. 2002;137:129-131. [pmid: 12118971].
Van Ballegooijen M, Habbema JDF, Boer R, Zauber AG, Brown ML. Report to the Agency for Healthcare Research and Quality: a comparison of the cost-effectiveness of fecal occult blood tests with different test characteristics in the context of annual screening in the Medicare population. August. 2003. http://www/cms.hhs.gov/coverage/download/id87.zip.
Van Rijn JC, Reitsma JB, Stoker J, Bossuyt PM, van Deventer SJ, Dekker E. Polyp miss rate determine by tandem colonoscopy: A systematic review. Am J Gastroenterol. 2006;101:343-350. [pmid: 16454841].
Vatn MH, Stalsberg H. The prevalence of polyps of the large intestine in Oslo: an autopsy study. Cancer. 1982;49:819-825. [pmid: 7055790].
Vogelstein B, Fearon ER, Hamilton SR, Kern SE, Preisinger AC, Leppert M, Nakamura Y, White R, Smits AM, Bos JL. Genetic alterations during colorectal-tumor development. N Engl J Med. 1988;319:525-532. [pmid: 2841597].
Vogelaar I, van Ballegooijen M, Schrag D, Boer R, Winawer SJ, Habbema JD, et al. How much can current interventions reduce colorectal cancer mortality in the U.S.? Mortality projections for scenarios of risk-factor modification, screening, and treatment. Cancer. 2006;107:1624-1633. [pmid: 16933324].
Whitney D, Skoletsky J, Moore K, Boynton K, Kann L, Brand R, Syngal S, Lawson M, Shuber A. Enhanced retrieval of DNA from human fecal samples results in improved performance of colorectal cancer screening test. J Mol Diagn. 2004;6:386-395. [pmid: 15507679].
Williams AR, Balasooriya BAW, Day DW. Polyps and cancer of the large bowel: a necropsy study in Liverpool. Gut. 1982;23:835-842. [pmid: 7117903].
Winawer SJ, Zauber AG, Ho MN, O’Brien MJ. Prevention of colorectal cancer by colonoscopic polypectomy. The National Polyp Study Workgroup. N Engl J Med. 1993;329:1977-1981. [pmid: 8247072].
Winawer SJ, Fletcher RH, Miller L, et al. Colorectal cancer screening: clinical guidelines and rationale. Gastroenterology. 1997;112:594-642. [pmid: 9024315].
Winawer S, Fletcher R, Rex D, et al. Colorectal cancer screening and surveillance: clinical guidelines and rationale-Update based on new evidence. Gastroenterology. 2003;124:544-560. [pmid: 12557158].
Winawer SJ, Zauber AG, Fletcher RH, et al. Guidelines for colonoscopy surveillance after polypectomy: a consensus update by the US Multi-Society Task Force on Colorectal Cancer and the American Cancer Society. Joint publication in. Gastroenterology. 2006;130:1872-1885. and CA Cancer J Clin 2006; 56: 143-159. [pmid: 16697750].
Yabroff KR, Davis WW, Lamont EB, Fahey A, Topor M, Brown ML, Warren JL. Patient time costs associated with cancer care. J Natl Cancer Inst. 2007;99:14-23. [pmid: 17202109].
Yabroff KR, Warren JL, Knopf K, Davis WW, Brown ML. Estimating patient time costs associated with colorectal cancer care. Med Care. 2005;43:640-648. [pmid: 15970778].