# Results

## Quality of the BPH Literature

We considered only controlled trials for this evidence report, because controlled trials provide an essential context for evaluating a new treatment. A properly blinded, randomized controlled trial (RCT) provides an additional benefit of minimizing the effects of extraneous variables, so that results can be attributed solely to the treatment being studied.

Use of a control group is particularly important in studies of BPH treatment. This is because men may enter studies when their symptoms are at their worst and, these symptoms will often improve even in the absence of treatment (a phenomenon known as “regression to the mean”). We comment on data demonstrating this phenomenon in the Results section. Sech et al.(24) have also documented the existence of regression to the mean in studies of BPH.

Most of the BPH studies included in this review randomly assigned patients to groups. Randomization obviates the need to match groups on patient characteristics and baseline disease severity, although these items are presented in the Evidence Tables. Also included are a few trials that were nonrandomized prospective or retrospective comparisons that appeared to have reasonably well-matched groups of patients. A few trials that assigned treatment on the basis of prostate size or other patient characteristics were considered to have non-comparable treatment groups, and were excluded.

Almost no trials reported whether patients were blinded to their treatment, and very few studies reported blinding of outcome raters. Such reporting of blinding was so rare that we did not comment on the lack of blinding with every comparison (although it is tabulated in the evidence tables), but rather pointed out the few trials where blinding was reported. Because of the strong potential for placebo effects in BPH symptom reporting, the lack of reporting of blinding may be a cause of bias in symptom results. That is, patients who knew they received the “new” treatment may have anticipated better results and may have had a substantially stronger placebo effect than patients who knew they received the control or standard treatment. Placebo effects in objective physiological measures such as Qmax are less of a concern.

### The need for equivalency trials

Medical statisticians(25–27) as well as regulatory agencies(28–33) have in recent years recognized that using trials to show that two treatments are equivalent (called “equivalency,” “non-inferiority,” or “active-control” trials) requires a clear a priori decision about the size of a clinically meaningful difference, a certain minimum study size, and appropriate statistical analysis (the null hypothesis must be reversed). Yet none of the relevant BPH trials were conducted or analyzed as equivalency trials. Using standard statistical tests designed to detect a “statistically significant difference” (typically with a p-value of 0.05) can be misleading in the absence of calculations demonstrating adequate statistical power. Yet most of the included BPH trials did not demonstrate adequate statistical power.

Because of these considerations, many of the studies that compare BPH treatments must be cautiously interpreted. Many of them are low-powered. If a study is too small to detect a clinically meaningful difference, the finding of “no statistically significant difference” can be misinterpreted as implying equivalence.(25,34–37) Further, the less statistical power a trial has, the easier it is to misinterpret its results. Smaller trials have less statistical power to detect clinically important differences with standard statistical significance thresholds (e.g., p-values of less that 0.05). Because of the danger of such misinterpretation, and because none of the BPH trials evaluated in this report were designed and analyzed as equivalency trials by their authors, we emphasize throughout this report that “no statistically significant difference” merely means the trial cannot conclusively demonstrate a difference, and does not imply equivalence. We caution the reader against misinterpretation of such findings.

### Confounds of high attrition and retreatment rates

Commonly, there were large discrepancies between the number of patients enrolled or treated and the number of patients in the results for the longest followup time. In most studies this did not appear to result from attrition, but rather because results were published before all patients had reached the longest time point (“right censoring”). While in many studies this caused the results at the longest time to be less reliable, nevertheless, this practice provided valuable information on the much-needed results at the longer time points. In general, the results at these longer time points did not appear to differ from similar time points in studies that waited for complete followup before publishing. Therefore, this large apparent discrepancy in some studies may not be a serious cause of bias.

Few, if any, of the included BPH trials were conducted strictly according to intention-to-treat principles. Few reported on patient exclusions that occurred after enrollment and before treatment, and those that did report this had negligibly small numbers of patients removed from trials in this manner. Therefore, this type of violation of intent-to-treat principles appears to be a negligible threat to validity. Patients who received a treatment almost always appeared to be kept with that treatment group for the reporting of results, even if they were subsequently treated with another treatment. Thus, in the important sense of having no crossovers, most of these studies conformed to intention-to-treat (the few exceptions are noted in the text and tables, if the authors provided such information).

In studies with high retreatment rates, interpretation of the results is difficult. In the case of dichotomous outcomes such as success/failure, retreatment could simply be counted as a treatment failure. However, there is no uniform definition of treatment failure, and few studies reported this outcome. Furthermore, recalculation and correction of reported results was beyond the scope of this technology assessment. For data that is not dichotomous, but is reported as means of continuous outcomes, there is no simple, reliable method for recalculating to account for high retreatment rates (say over about 10%). There are three possible ways authors might handle this difficulty, and they all may lead to an overestimation of the efficacy of an intervention with a high retreatment rate. If the authors excluded the retreated patients, then the remaining patients were the patients with the best response to treatment. If the retreated patients were included as part of the analysis of results of the initial treatment, then the results not only reflect the efficacy of that treatment, but also the retreatment method, possibly inflating estimates of efficacy. If the authors crossed over the retreated cases to the arm for the retreatment method, that would be a violation of intention-to-treat principles and a threat to the original randomization. Because of these problems, retreatment rates were important to consider in arriving at our conclusions, and we treated with caution those trials that reported a high retreatment rate. In such trials, the retreatment rate itself might be the most important and only interpretable outcome.

### Adverse events

In the present literature, treatment-related adverse events are incompletely reported, or are reported using different terminology and definitions. Further, many studies were too small to detect adverse events or to provide reliable rates of occurrence. If the authors did not report an adverse event, one cannot determine whether the event did not occur or if it was simply not reported. These difficulties prevented a quantitative evaluation of adverse events in this report. In the evidence tables, we included all reported adverse events as described by authors, and considered them in assessing results.

### FDA Product Labeling

In evaluating the literature, it is important to determine if a given trial is applying the treatment to the population that was studied when the device received FDA marketing approval or clearance. Treatments may not be as effective for patients for whom the device or treatment was not designed. For example, treating patients with large prostates with certain laser or other heat-based treatments may not be as effective as with patients with smaller prostates for whom the treatment was intended.

Where appropriate, we mention FDA clearance indications and contraindications in the text. Full product labeling indications and contraindications for devices are provided in Appendix F. Such information was not available for all devices because many devices cleared under 510k regulations are cleared for general uses (such as many of the lasers).

## Standard Surgical Treatments

### Transurethral resection of the prostate (TURP)

#### Technology Description and Clinical Issues

TURP is considered the current standard of care for surgical treatment of BPH in most patients and has been the primary choice of treatment for the past 50 years.(3,6,19,38,39) TURP is an endoscopic procedure that requires general or spinal anesthesia and takes 30 to 60 minutes to perform. In TURP, the surgeon inserts a resectoscope, a 12-inch long, ½ inch diameter scope that contains a light, irrigating fluid valves, and a wire-loop electrode (approximately 0.3 millimeter in diameter) for cutting and coagulating. An electrosurgical generator is used to power the electrode, usually to 120 W or 150 W. The surgeon uses the wire-loop electrode to remove tissue that is obstructing or pressing against the urethra. Prostatic tissue is generally removed until the capsule is reached. Irrigating fluid maintains the surgeon’s visibility and carries the resected pieces of tissue (chips) into the bladder, which is then flushed out at the end of the TURP procedure. Higher electrosurgical frequencies may be used for coagulation during TURP. Recently, European urologists introduced a high-frequency technique called “coagulating intermittent cutting” that is intended to reduce perioperative blood loss in patients at increased risk for bleeding.(40)

Until recently, TURP procedures were performed using monopolar electrosurgery, in which an active electrode is located in the surgical handpiece, and a dispersive (return) electrode is placed on the patient (usually on the outer thigh or lower abdomen). The dispersive electrode, also called a grounding pad, directs electrical current flow from the patient back to the power unit and reduces current density as energy flows from the patient, thereby minimizing the possibility of burns at the return electrode. In bipolar TURP, much of the instrumentation and surgical technique are the same as for monopolar TURP. A dedicated bipolar electrosurgical generator may be used, but some general electrosurgical devices can be used for both modes. Also, both modes can be used in the same procedure, for example, for cutting and coagulating. Dual wire-loop electrodes are used, in which the active and return electrodes are located in one handpiece, and the electrosurgical current flows between the electrodes through conducting saline, rather than from the active wire-loop electrode, through the patient to the grounding pad (dispersive electrode) as in monopolar TURP. Therefore, the dispersive electrode pad placed on the patient is not required in bipolar TURP. Because of the differences in energy delivery, bipolar TURP can result in less granulation tissue and less tissue charring than monopolar TURP. However, bipolar TURP requires slower movement of the wire-loop electrodes. Bipolar electrodes require less power than monopolar electrodes, because there is less tissue between the electrodes to create impedance.(41)

Monopolar TURP requires the use of a nonconducting irrigation fluid. Sterile water was used up until the 1940s, when it was abandoned because of problems with hemolysis.(42) The current standard irrigant is 1.5% glycine, although mannitol and sorbitol have also been used.(42) Absorption of excess irrigation fluid into the blood stream can cause TURP syndrome, which can include hyponatremia, nausea, temporary blindness, unconsciousness, and rarely death.(7) Bipolar TURP requires saline for current conduction between the two electrodes. This has the potential to eliminate TURP syndrome. However, the use of saline in the narrow urethra introduces the potential for inadvertent damage to non-targeted tissue.

Our searches identified no controlled studies directly comparing mono- and bipolar techniques. Only one of the trials included in the present analysis reported which method was used (monopolar),(43) possibly because both methods are considered versions of the standard TURP procedure. Therefore, there is insufficient evidence to draw conclusions about the comparative effects of these two techniques on patient outcomes.(8–11)

It is considered undesirable to have a TURP procedure last longer than 60 minutes, because of potential blood loss and irrigation fluid absorption. This has the practical effect of preventing the use of TURP for patients with very large prostates beyond the 70 to 100 grams range,(19,44) and such patients may require open prostatectomy.

TURP requires catheterization for 24 to 48 hours, and a hospital stay ranging from one to five days. In addition, for at least four weeks after TURP, patients may have restricted physical activity.

In a recent landmark study by Borboroglu and colleagues of 520 consecutive TURP patients from 1991–1998,(45) the rate of intraoperative complications was 2.5%, immediate postoperative 10.8%, and late complications 8.5%. The transfusion rate was 0.4%. There were no mortalities, meaning the rate was less than 0.2% (1/520). The rate of repeat TURP was 2.5%, with mean followup of 42 months (range: 6 to 84 mos.). These authors found great improvements in all the above rates compared to compilations from previous eras that have often been used by proponents of new treatments in retrospective comparisons to historical controls. In the first year of the Borboroglu study (1991), the catheterization time was 3.5 days and hospital stay 3.8 days, but these were reduced to 1.8 and 1.1 days, respectively, for the last year of the study (1998). These large improvements in results over time suggest that even the rates cited in this most recent study may overestimate the TURP complication rates observed in current practice. This indicates the unreliability of comparing uncontrolled study results to historical data. Thus, we base our report mostly on controlled studies in which new treatments were compared directly to a concurrent TURP group.

In 21 controlled trials included in the present report with TURP groups with followup of at least 12 months, the retreatment rate in the TURP groups ranged from 0% (0/35)(43) to 30% (13/43)^2^.(46) However, the definitions of “retreatment” in these trials were not consistent. Trials with smaller retreatment rates appeared to refer only to TURP retreatment for LUTS, whereas, trials with larger rates appeared to refer to any urological surgical intervention for any reason during followup. Because of the lack of a consistent definition, as well as other between-study differences, across-studies comparisons of retreatment rates are inappropriate in this body of evidence, and the reader is advised to consider only the within-studies comparisons of retreatment rates. Because of the small size of many of the studies and the low frequency of retreatment, even the within-studies retreatment rate comparisons may not be reliable.

2 Adverse event and reoperation rates are always provided with raw numbers as well in this document, unless the authors did not report the number of patients that the statistic was based on.

TURP is performed with general surgical devices such as electrosurgical units, electrodes and endoscopes. These devices are cleared for marketing in the United States through the Food and Drug Administration’s 510(k) premarket notification process.(47)

#### Clinical Practice Guidelines

In 2000–2001, the Fifth International Consultation on BPH (ICBPH), sponsored by the World Health Organization (WHO) and the Union Internationale Contre le Cancer (UICC), established recommendations for the diagnosis and treatment of BPH, lower urinary tract symptoms, and bladder outlet obstruction.(48) Recommendations were based on a literature review and opinion of international clinical experts. The Fifth ICBPH considers TURP the “gold standard of interventional therapy” for BPH,(5,19) but suggests that, because morbidity, mortality, and blood transfusion rates are directly related to resection time, TURP should only be performed if the resection can be completed in one hour.(19) The European Association of Urology (EAU) recommends surgical management using TURP, TUIP, or open prostatectomy as a first-line treatment for patients with bothersome BPH symptoms refractory to medical treatment.(49) The AUA also considers TURP to be “the gold standard” for BPH treatment.(3)

As TURP is the current standard of care, it is outside the scope of this report to provide a detailed analysis of its efficacy. The above comments are provided as background information.

### Transurethral electrovaporization procedures

#### Technology Description and Clinical Issues

Transurethral electrovaporization of the prostate (TUEVP, TUVAP, or TUEVAP; also called transurethral vaporization, TUVP or TVP, or transurethral evaporation, TUEP) has developed since the early 1990s as a variation of TURP. TUEVP and TURP are similarly performed in that both use a standard resectoscope inserted transurethrally, and an electrosurgical unit to deliver energy to an electrode. Thus, TUEVP is considered a modification of TURP.(19,50–52)

Electrovaporization procedures differ from TURP and each other according to the type of electrode used and the magnitude of electrical energy applied, both of which determine whether tissue is incised, vaporized, resected into pieces or “chips”, or coagulated. In general, the electrodes used in vaporization procedures are shaped and sized to allow more tissue contact than the standard thin wire loop electrode used for resecting. Prostatic tissue is vaporized using a grooved or spiked rollerball or thicker band-loop electrode. Wire loop electrodes used for electrovaporization are approximately one millimeter in diameter. Due to the high energy and simultaneous vaporization/coagulation of prostate tissue, TUEVP procedures can produce less bleeding than TURP.(19,53,54) After the electrode is inserted through the resectoscope to the area to be treated, an electrical current of 230 to 300 W is applied to heat the obstructing prostate tissue until it turns to steam. A constant flow of irrigating fluid is applied to the heated area to dissipate heat. According to clinicians, TUEVP is difficult to perform in prostates larger than about 50 grams, because of the longer operative times required.(55)

“Sandwich techniques” have been developed that use the rollerball electrode to vaporize and coagulate first, followed by the standard TURP wire-loop electrode to resect coagulated tissue, and then the rollerball electrode again to complete dissection and coagulation of deeper tissue. In this report, we refer to any technique combining vaporization and resection as transurethral vaporization with resection of the prostate (TUVRP). The “sandwich technique” allows tissue to be removed for pathologic analysis.(53) In addition to the sandwich technique, TUVRP can also be performed with a single thicker loop or band electrode. This enables more contact with prostate tissue than the TURP thin wire-loop electrode, to simultaneously vaporize, cut, and coagulate, without alternating the electrode used. For cutting, energy of 230 to 300 W is used, and for coagulation, energy of 50 to 80 W is used. Regardless of the power setting, the actual power delivered depends on the impedance of the tissue. Too low power can result in less efficient cutting and excess coagulation necrosis, which is considered a cause of persistent postoperative irritative symptoms.(53) Some power generators have the ability to increase current with changing tissue impedance. With TUVRP, resection of tissue “chips” is possible, although cutting times are longer than with TURP because of the time required for vaporization and coagulation. In 2002, a bipolar electrosurgical generator for plasma vaporization and resection was introduced and is being studied in comparison to TURP and TUVRP.

Electrovaporization procedures can be performed on an outpatient basis or with an overnight hospital stay. Depending on the patient, general or regional anesthesia, and/or intravenous sedation with local intraurethral analgesic are used. Theoretically, vaporization causes less bleeding because the treated tissue is coagulated and sealed by the higher applied energy and the electrode design (the evidence for this is addressed below). TUEVP and TUVRP are considered easy to teach and learn, because of the similarity to TURP in equipment and technique, and the better visibility due to less bleeding.(52)

In our analysis comparing TUEVP with TURP, we considered all TUEVP procedures as a group and did not separate results based on the many different electrode designs. This is in accordance with the way the procedure is commonly categorized by clinicians in the literature. We considered TUVRP to be a separate technique and analyzed these trials separately.(55)

TUEVP and TUVRP are performed with general surgical devices such as electrosurgical units, electrodes and endoscopes. There are many electrodes with different shapes for TURP, TUEVP and TUVRP. The electrodes used in the included trials in the present report are listed in the evidence tables that accompany this report. These devices are cleared for marketing in the United States through the Food and Drug Administration’s 510(k) premarket notification process.(47)

#### Clinical Practice Guidelines

The Fifth ICBPH views TUEVP as a variation of the standard TURP procedure that results in less bleeding, and has considered TUVRP an “acceptable” BPH treatment since 1997.(19) The AUA concluded(56) that TUEVP shows equivalent short-term symptom improvement to TURP, but has higher rates of postoperative irritative urinary side effects. The AUA states that long-term comparative trials are needed to compare transurethral vaporization to standard TURP. In addition, the AUA considers the newer bipolar plasma vaporization technique an emerging therapy requiring additional data before it can be recommended as a treatment option. The procedure can be offered to appropriate patients, provided outcomes relative to recommended treatments are discussed with the patient.(3)

#### Findings

- Symptoms and peak urinary flow rates are similar after TUEVP, TUVRP and TURP. Quality of life is also similar after TUEVP and TURP. Both hospitalization time and catheterization time are shorter for TUEVP.

Seventeen controlled trials compared TUEVP or TUVRP with TURP (N ≥1,100), all but one of which were randomized.(44,50–52,55,57–70) Most studies that reported size criteria excluded patients if their prostates were over 60 or 70 grams. Most trials had data at one year, one trial at two years and one at three years. Thirteen trials evaluated TUEVP, while four trials used a combination of cutting and vaporization (TUVRP).(55,57,58,66)

##### TUEVP

Twelve trials on TUEVP reported symptom severity. In general, after TUEVP and TURP, patients’ symptoms improved from severe to mild, and patients’ IPSS scores were similar. TUEVP and TURP also provided similar peak urinary flow rates (Qmax; reported by 15 trials). Five(50,57,60,61,63,71) of the 13 trials on TUEVP reported quality of life (QoL) data, and, again, similar results were observed after the two treatments.

The number of patients with retention, stricture, incontinence or retrograde ejaculation was similar after TURP and TUEVP. Five studies reported on post-operative irritative symptoms (caused by sloughing of necrotic tissue). Four of these trials reported more such symptoms with TUEVP than with TURP.(50,60,67,69) However, in one trial, the rates were similar.(61)

Two trials reported retreatment rates.(63,68) These rates tended to be lower after TURP but rates were so low for both groups that reliable comparisons cannot be made.

Results for operation time wee mixed: operation time was shorter for TUEVP in two trials,(51,65) shorter for TURP in two(50,61,70) and the same in two.(60,67) Catheterization time was shorter for TUEVP in seven of eight trials reporting.(50,51,61,65,67, 68, 70) Hospital stay was shorter for TUEVP in four of five trials reporting this result.(50,61,68,70)

##### TUVRP

Four trials evaluated TUVRP(55,57,58,66) and found that results were similar for TUVRP and TURP for symptoms and physiological outcomes. Across trials TUVRP and TUEVP showed similar results for symptoms and physiological outcomes, although there was no such direct comparison in any trial.

Operation time was longer for TUVRP in two trials(55,58) and the same in two.(57,66) Catheter time was shorter for TUVRP in one trial (48 hrs, vs 96 hrs,)(58) and the same in one (3.4 and 3.3 days).(66) Hospital stay was shorter for TUVRP in the only trial reporting this result (2.5 days vs 4.5 days).(58)

### Open prostatectomy

#### Technology Description and Clinical Issues

Open prostatectomy is a major surgical procedure in which the obstructing prostate tissue is removed through a lower abdominal incision using a suprapubic (through the bladder) or retropubic (through the prostate capsule) approach. The obstructing tissue is excised in one piece, and the prostate capsule is not removed. (In radical prostatectomy, a treatment for prostate cancer, the entire prostate and capsule are removed.) Open prostatectomy requires general or spinal anesthesia, a three- to five-day hospital stay, and a longer period of catheterization and recovery than TURP. Open prostatectomy is one of the only treatment options for patients with prostate glands greater than 75 to 100 grams,(19,44) and is also performed in patients with other conditions, such as bladder stones, that require an open procedure.(19,49) Therefore, today TURP and open prostatectomy are considered for different populations of patients, and are not considered to directly compete with each other.

In the past, although TURP may have been no better than open prostatectomy in terms of symptom improvements and not quite as efficacious in terms of physiological measures, these differences were considered to be outweighed by the shorter operation times and less blood loss. This accounts for TURP’s historical replacement of open prostatectomy as the “gold standard” surgical treatment for BPH, except for men with very large prostates beyond the 70 to 100 grams range.

As a surgical procedure, open prostatectomy is not regulated by the FDA.

#### Clinical Guidelines

The Fifth ICBPH considers that open prostatectomy is “acceptable,” and that it is necessary for patients with prostates larger than 80 to 100 grams. The EAU recommends surgical management using TURP, TUIP, or open prostatectomy as a first-line treatment for patients with bothersome BPH symptoms refractory to medical treatment.(49)

#### Findings

- There are no current direct comparisons of open prostatectomy to TURP. Open prostatectomy and TURP are now used on different patient populations.

There has been only one controlled trial comparing open prostatectomy with TURP, a randomized study by Meyhoff (N = 75) in the 1970s.(46,72) The efficacy and complications for these procedures at that time are likely not relevant to current practices; TURP and open prostatectomy are now considered to have different indications and patient populations.(19)

### Transurethral incision of the prostate (TUIP)

#### Technology Description and Clinical Issues

TUIP is a surgery that is less invasive than TURP and is usually limited to small prostate glands. In TUIP, the surgeon makes one or two lengthwise internal incisions in the prostate near the bladder, which opens the bladder neck and prostate to reduce pressure on the urethra. Either a laser system or electrical current delivered via an electrosurgical unit can be used to make the incisions (only electrosurgical incisions are considered in this section; laser surgeries are considered in other sections). Because TUIP is less invasive than TURP, it can be performed on an outpatient basis under regional or general anesthesia, although a one- to three-day hospital stay may be required. Although the incision itself does not provide prostate tissue for histological detection of prostate cancer, a biopsy can be taken through the resectoscope at the time of the procedure.(73)

TUIP is performed with general surgical devices such as electrosurgical units, electrodes and endoscopes. These devices are cleared for marketing in the United States through the Food and Drug Administration’s 510(k) premarket notification process.(47) They are not generally cleared for specific indications.

#### Clinical Practice Guidelines

TUIP is performed on patients with small prostate glands. The World Health Organization recommends restricting the use of TUIP to patients with prostates 30 grams or less in size.(6) The European Association of Urology (EAU) recommends TUIP for patients with a small prostate gland, no median lobe, and a low risk of associated prostate cancer.(49) The Fifth ICBPH suggested that TUIP can be used to treat prostates up to 80–100 grams in size, but is particularly suited for treating prostates of less than 30 grams.(19) The EAU recommends surgical management using TURP, TUIP, or open prostatectomy as a first-line treatment for patients with bothersome BPH symptoms refractory to medical treatment.(49)

#### Findings

- TUIP is intended for men with small prostates. TUIP and TURP provide similar symptom relief. TUIP results in lower retrograde ejaculation rates and shorter operation times, as well as shorter catheterization times and hospital stays than TURP. However, TURP results in higher peak urinary flow rates than TUIP.

We identified 10 randomized trials (N = 811) comparing TUIP to TURP.(73–85) Most of these trials followed the majority of patients for two to three years. These trials included only men with prostates smaller than 20 to 40 grams. In these trials, the symptom relief for the two treatments appears similar, but peak urinary flow rate (Qmax) was higher after TURP. None of the studies reported data on quality of life.

After TUIP, operation time, days in hospital, and catheterization time were shorter or similar to TURP, and a lower or a similar percentage of patients required transfusions. While most adverse events were similar, the retrograde ejaculation rate was lower after TUIP.

Retreatment rates were reported in four trials.(74,76,77,80) In three of the four trials, retreatment rates appear higher for TUIP than for TURP. One study of 85 patients (Jahnson 1998) reported that this difference was statistically significant (23% versus 5% retreatment rates),(76) while two reported no statistical tests and one reported no statistically significant differences (exact rates not available). However, because the number of patients enrolled in each of these trials was either not reported or was often small (<35 patients per group) and the number of patients requiring retreatment was also low (typically <10), comparison of rates may not be reliable.

The 5-year trial by Jahnson et al. (1998)(76) carried out cystoscopy at 2 years and found adhesions, closed incisions or obstructing lobes in 90% (19/21) of the TUIP patients compared to 39% (9/23) of the TURP patients (statistically significant). A comparable difference was observed at five years. These authors concluded that these findings explained why Qmax is lower and the retreatment rate is higher for TUIP.

## Laser Surgical Treatments

### Transurethral ultrasound-guided laser-induced prostatectomy (TULIP)

#### Technology Description and Clinical Issues

TULIP was introduced in 1990 and was one of the first laser procedures used for BPH. TULIP is performed with a right-angle-firing Nd:YAG laser probe housed between two ultrasound transducers that are used for real-time sector scanning to position the laser while it is being fired. The laser is fired while the device is moved and rotated through the urethra from the bladder neck to the verumontanum. Coagulation necrosis of the prostate tissue produces shrinking over several weeks following the procedure.

TULIP has been replaced by other laser types and techniques (discussed in subsequent sections) that have fewer side effects, shorter postoperative catheterization times, and fewer urinary symptoms. The most recent controlled trial of TULIP was a retrospective review published in 1998 by Japanese researchers, and the patients had likely received the procedure several years before then.(86)

#### Clinical Practice Guidelines

TULIP is not mentioned in any of the evidence-based BPH guidelines that we identified.

#### Findings

Because this treatment appears to be outdated, we do not further consider the results of controlled trials on it.

### Contact laser ablation of the prostate (CLAP)

#### Technology Description and Clinical Issues

Surgeons developed CLAP in the early 1990s in an attempt to avoid the intraoperative complications of TURP, such as blood loss. To perform CLAP, the surgeon places the tip of an Nd:YAG laser in direct contact with the prostatic tissue, which vaporizes it. The laser tip is slowly dragged to create “furrows” across the prostate, thereby reducing prostatic obstruction of the urethra. While the primary mechanism of action in CLAP is vaporization, some tissue coagulation also occurs. As a result, patients require postoperative catheterization to permit sloughing of any coagulated tissue. Unlike TURP, CLAP does not yield samples that can be tested for prostate cancer. CLAP requires extensive training and experience, and some have suggested that a surgeon’s first set of cases be restricted to patients with smaller prostates because they are easier to treat.

Results from one RCT suggested that some surgeons experienced difficulty in performing CLAP in patients with prostates of 40–50 grams.(87) We identified a single laser FDA cleared specifically for use during the CLAP procedure: Surgical Laser Technologies’ SLT CL MD (Nd:YAG) Contact Laser System and delivery fibers.(88) This laser is cleared only for prostates up to 45 grams.

#### Clinical Practice Guidelines

The AUA 2003 Guidelines(3) classify CLAP as a surgical approach to BPH and states that the choice of surgical approach is a technical decision based on patient’s prostate size, surgeon judgment, and patient’s comorbidities. The AUA also states that, while CLAP results in short-term improvements (symptom scores, urinary flow rate) equivalent to TURP, reported rates of postoperative urinary retention and unplanned secondary catheterization are higher following CLAP.

The Fifth ICBPH(19) recommends holmium laser treatment and ILC over CLAP due to CLAP’s higher treatment failure rates and complications. The EAU(49) does not discuss CLAP in its review of laser therapy, but recommends that side-firing VLAP and ILC be used only for patients on anticoagulants, for patients not eligible for TURP, or for patients with a desire to maintain ejaculation.

#### Findings

All five of the trials comparing CLAP to TURP used sapphire-tipped laser probes and fibers (MTRL 10) manufactured by Surgical Laser Technologies (Oaks, PA, USA). Four of the five trials used an Nd:YAG laser generator manufactured by the same company,(71,89–91) and the fifth trial used an unspecified Nd:YAG laser generator.(89) There were no controlled trials comparing CLAP devices. However, the similarities among the CLAP devices in these five trials support the grouping of their results.

- CLAP and TURP resulted in similar improvements in physiological measures. CLAP and TURP provided similar symptom relief and similar quality of life improvements in most trials, but one double-blinded RCT found these outcomes to be less improved after CLAP than after TURP. CLAP results in less blood loss than TURP.

Five controlled trials (N = 346) compared CLAP to TURP.(71,87,89–95) These trials were all randomized, and one was a double-blinded trial that followed patients for three years (the Oxford Laser Prostate trial).(87,91–94) In that trial, symptoms were worse at three years for patients who received CLAP than for those who received TURP(statistically significant). The other four trials found that symptom scores after CLAP and TURP were similar. All five trials found that physiological measures such as Qmax were similar for CLAP and TURP after treatment.

The Oxford trial found that one year after treatment, BPH-specific quality of life was slightly worse after CLAP than after TURP (statistically significant). However, quality of life using other measures in other trials was similar after the two treatments.

Two trials reported retreatment rates.(87,89,91,94) Keoghane et al. (2000) reported that patients who received CLAP were more likely to require retreatment by three year followup than those who received TURP (18% vs 9%) (statistical significance not reported). The authors suggest that this difference may have been caused by surgeons’ limited experience with CLAP.(91) Another possible explanation is the inclusion of patients with large prostates, who are more difficult to treat and may be less appropriate for CLAP. Three of the five trials(89,90,95) either excluded patients with large prostates (e.g., >40 grams) or required surgeons to have performed a minimum of 20 previous CLAP procedures.(90) One of these three trials (Tuhkanen et al., 1999)(89) reported that no patients in either group required retreatment, suggesting that it enrolled too few patients to reliably determine retreatment rates.

Operation times for CLAP and TURP were generally similar (30–40 minutes), but two trials reported that during CLAP, patients lost significantly less blood (37–59 mL versus 175–200 mL during TURP).(89,91)

Three of the five trials reported comparative data on adverse events. One trial (N = 32) found a statistically significantly lower rate of retrograde ejaculation after CLAP than after TURP (6% versus 81%).(89) None of the other trials reported retrograde ejaculation rates. No other statistically significant differences in adverse event rates were reported, but it is possible that the trials enrolled too few patients to detect such differences.

### Visual laser ablation of the prostate (VLAP)

#### Technology Description and Clinical Issues

In VLAP,^3^ the Nd:YAG laser is held a short distance (2 mm) from the prostate tissue (unlike CLAP in which there is direct tissue contact, see previous section). The primary mechanism of tissue destruction is coagulation rather than vaporization, and the coagulated tissue sloughs away over the next several weeks. Therefore, VLAP requires longer postprocedural catheterization times ranging from five days to several weeks, and may require recatheterization. During the sloughing period, patients may also experience infection, swelling, and pain during urination. Several variations of VLAP have been developed that use different types of lasers, laser fibers, wattages, and application techniques. Unlike TURP, VLAP does not yield samples that can be tested for prostate cancer.

3 VLAP is also referred to as non-contact laser ablation of the prostate or laser coagulation of the prostate.

VLAP is typically reserved for patients with small or moderately-sized prostates (<80 grams), because patients with larger prostates would require multiple sessions. Patients with chronic urinary tract infection or bacterial prostatitis are not good candidates because coagulated tissue may become infected.(19) VLAP may be particularly appropriate for patients who are on anticoagulants because the laser seals blood vessels.

VLAP devices that have received FDA 510(k) clearance to be marketed in the treatment of BPH include Trimedyne’s Optilase Nd:YAG Laser System Models 1000, 4000, and 1000–100 (PL100) used with Trimedyne’s UroGold or UroMax Right Angle Laser Fibers, and Laserscope’s 800 Series and Orion Series KTP/Nd:YAG Surgical Laser Systems used with the Angled Delivery Devices (ADD Family Product Line). The Trimedyne system is indicated for coagulation of soft tissue for prostatectomy in the treatment of BPH. The FDA clearance did not mention whether the device was indicated for patients with specific prostate sizes. The Laserscope system is indicated for men 50 years and older with prostatic volumes of 60 cc or less.

#### Clinical Practice Guidelines

The AUA Guidelines(3) classify VLAP as a surgical approach to BPH and states that the choice of surgical approach is a technical decision based on patient’s prostate size, surgeon judgment, and patient’s comorbidities. AUA also states that, while VLAP results in short-term improvements (symptom scores, urinary flow rate) equivalent to TURP, reported rates of postoperative irritative voiding and unplanned and prolonged postoperative catheterization are higher following VLAP.

The Fifth ICBPH(19) classifies VLAP as an “acceptable” treatment, but recommends holmium laser treatment and ILC over VLAP due to higher retreatment rates and complications. The EAU guideline(49) does not recommend VLAP as a first-line therapy, but advises that VLAP be used only for patients on anticoagulants, for patients not eligible for TURP, or for patients with a desire to maintain ejaculation.

#### Findings

Ten trials compared VLAP to TURP. Eight of these trials(95–102) used the Urolase fiber (Bard, Covington, GA, USA), one(103) used the Ultraline fiber (Lasersonics, Tokyo, Japan), and one(63) used the ADD fiber (Laserscope, San Jose, CA, USA). No controlled trials of VLAP have compared these fibers, thus one cannot determine from direct evidence whether the different fibers in these studies affected results. Regarding laser generators, seven(63,97–102) used an Nd:YAG laser from an unspecified manufacturer, one(103) used the Hercules 5060 Nd:YAG laser generator (Lasersonics, Tokyo, Japan), one(96) used the Trimedyne Nd:YAG laser (Trimedyne, Irvine, CA, USA), and one(95) used the SLT Nd:YAG laser (Surgical Laser Technologies, Oaks, PA, USA). As with the fiber differences, because of the lack of controlled trials comparing generators, one cannot determine whether device differences could have affected outcomes.

- One year after surgery, symptoms and quality of life improvements are similar after VLAP and TURP. VLAP requires shorter hospitalizations and longer catheterization times than TURP. Two trials report that major adverse events are less likely after VLAP than after TURP. Three trials report that patients who receive VLAP are more likely to require retreatment than patients who receive TURP.

Ten trials (eight of them randomized) compared VLAP to TURP.(63,64,95–108) The trials enrolled over 1,057 patients. One of these, the CLASP randomized trial, also included a group of patients who received only “conservative management,” and VLAP patients fared significantly better in symptom score improvement than those patients.(100,105,109) Of eight studies reporting IPSS scores at 6–8 months of followup, four(63,64,98,101,102) reported statistically significantly fewer symptoms after TURP than after VLAP. None of the three studies reporting twelve month or longer followup reported any statistically significant differences in IPSS scores.(63,64,95,97) Four of five studies reporting quality of life data found no statistically significant differences between VLAP and TURP.(63,64,96,100–102,104–108) Of five studies reporting peak urinary flow rates at one year or longer, two(95,96,106–108) found no significant differences between VLAP and TURP, and three(63,64,97,99) did not report statistical tests of this outcome.

Of four trials reporting operation times, one study with multiple publications(96,106–108) reported statistically significantly shorter operation times for VLAP than for TURP, one study(95) reported no statistically significant difference, and the other two studies(100,103–105) did not report statistical tests of this outcome. Of eight trials reporting hospitalization times, five(95,96,100–102,104–108) reported that it was statistically significantly shorter after VLAP than after TURP. Of eight trials reporting catheterization times, four(63,64,100–102,104,105) reported that catheterization times were statistically significantly longer after VLAP than after TURP. Of seven trials(63,64,96,97,99–101,103–108) reporting rates of blood transfusion, one study with multiple publications(96,106–108) reported statistical tests of this outcome, and it reported no statistically significant difference.

Two trials reported that significantly fewer major adverse events (e.g., urethral stricture) occurred in patients who receive VLAP than those who received TURP (8–11% VLAP versus 30–36% TURP).(96,101)

Three prospective trials reported retreatment rates,(99,101,102) and they all found that retreatment was more common after VLAP than after TURP (7–9% versus 0–4%, respectively).

- CLAP and VLAP yield similar improvements in symptoms and peak urinary flow rates. The findings on retreatment rates are mixed.

Three RCTs with one to two year followup compared CLAP to VLAP.(95,110,111) Both treatments reduced symptoms in all three trials to a similar degree. Peak urinary flow rate (Qmax) also improved similarly after both treatments.(95,110,111) Findings on retreatment rates, reported by two trials, were mixed; Narayan, 1995(111) found that 0/32 (0%) CLAP patients required retreatment as compared to 5/32 (16%) of TURP patients (statistically significant difference). Bryan (2000)(110) reported similar retreatment rates after CLAP and VLAP (4.8%, or 1/21 patients versus 11.8% or 2/17 patients) but may have had insufficient statistical power to detect a difference in retreatment rates.

Three trials reported catheterization time; although Bryan, 2000 found longer catheter times after VLAP (13.2 days versus 4.5 days for CLAP)(110), the other two trials did not find such differences (one to two days for both treatments).(95,111)

- One RCT reported long-term results comparing VLAP to hybrid laser and found similar results on symptoms, peak urinary flow rates, retreatment, adverse events rates, and perioperative outcome measures for the two treatments.

One RCT (N = 93) with three-year followup compared VLAP with Urolase fiber to a hybrid laser technique using the Ultraline fiber.(112–114) Symptoms, physiological measures, retreatment, adverse events, and perioperative measures were all similar after the two treatments.

### Holmium laser treatment

#### Technology Description and Clinical Issues

Surgical use of the holmium laser for BPH has evolved since its original introduction in 1994. Initially, holmium laser ablation of the prostate (HoLAP) was performed and involved the use of side-firing and end-firing laser fibers to vaporize and ablate prostate tissue. Relief of obstruction is immediate, unlike other laser procedures such as VLAP in which benefits are seen only after a delay. However, HoLAP does not yield tissue for histologic analysis, therefore surgeons later developed holmium laser resection of the prostate (HoLRP).

In HoLRP, the surgeon resects prostate tissue into pieces small enough to be removed with bladder irrigation and grasping forceps or a modified resectoscope loop. Compared to TURP, however, HoLRP yields less tissue for analysis, and the available tissue is of lower quality due to thermal artifacts.(115) These problems, in addition to relatively long operation times, motivated the development of Holmium laser enucleation of the prostate (HoLEP) in conjunction with a tissue morcellator.

In HoLEP, an entire prostatic lobe can be separated from connective tissue and deposited into the bladder. The removal of intact lobes is similar to open prostatectomy, discussed above. The morcellator then extracts the tissue from the bladder without using heat, thereby preserving tissue volume and quality. Bladder injuries related to careless operation of the morcellator have been reported; distension of the bladder can prevent the bladder mucosa from being drawn into the blades.(116) In the Findings section below, the three Holmium procedures (HoLAP, HoLRP, and HoLEP) are discussed separately.

Prostate size is an essential factor in the choice of holmium laser procedures. For patients with small prostates, HoLAP may still be appropriate,(116) and incision of the bladder neck using the holmium laser is another alternative.(115) Moderately-sized prostates can be treated with HoLRP.(117) One possible advantage of HoLEP is that with sufficient surgical expertise, it can be applied to very large (>100 grams) prostates.(115)

An advantage of the holmium laser is the ability to coagulate tissue simultaneously with tissue incision, vaporization, resection, or enucleation. This reduces intraoperative blood loss as well as postoperative bleeding. However, holmium lasers are expensive, and the surgical procedures generally require extensive training.(115–117) Therefore, fewer urologists are likely to offer this treatment option to patients. A minimum of 20–30 cases using HoLEP on small prostates may be necessary before a surgeon is sufficiently skilled to treat patients with larger prostates.(116)

Many holmium lasers have been FDA approved for general urological indications. Among them, specifically listing HoLEP, HoLAP, and HoLRP as intended uses, is the Modified Lumenis VersaPulse PowerSuite Holmium and Dual Wavelength Surgical Laser System.(FDA clearance product number K011703).(118) The system is indicated for use in a variety of urological indications including BPH, lithotripsy, and tumor removal. The FDA clearance did not mention whether the device was indicated for patients with specific prostate sizes.

#### Clinical Practice Guidelines

The Fifth ICBPH favors the use of the holmium laser over CLAP and VLAP, although they emphasized that there is a steep learning curve associated with holmium laser use.(19) The ICBPH guidelines also stated that prostates larger than 100 grams are a relative contraindication, but noted that the development of morcellators has improved retrieval of larger prostate fragments from the bladder. The EAU guidelines recommend laser prostatectomy using side-firing lasers or interstitial laser coagulation (ILC) for patients who are on anticoagulant medication, who are not candidates for TURP, or who desire to maintain ejaculation. The EAU noted that holmium laser resection/enucleation is a promising technique with outcomes similar to TURP.(49) The AUA considers holmium laser resection/enucleation an alternative to TURP in medical facilities that have the technology and training.(3)

#### Findings

##### Holmium Laser Ablation of the Prostate (HoLAP)

The only study available evaluating HoLAP(119) used the VersaPulse Select laser (Lumenis, Santa Clara, CA, USA). Two fibers were used: the Slimline 550 (Lumenis, Santa Clara, CA, USA) or the Duo-Tome Sidelite (Lumenis, Santa Clara, CA, USA).

- One controlled trial reported that symptoms and physiological measures improve to a similar degree after HoLAP and TURP. This RCT also reported that HoLAP operations take longer than TURP operations.

One RCT (N = 36) compared HoLAP to TURP (Mottet et al. (1999)(119) with one-year followup. Symptoms and physiological measures improved to a similar degree after both HoLAP and TURP. However, this is based on only 36 patients.

Mottet et al. (1999)(119) found that HoLAP operations took statistically significantly longer (mean 75 minutes) than TURP operations (mean 40 minutes), but they found no differences in other perioperative measures. Enrollment may have been too low to reliably detect differences in adverse events between HoLAP and TURP. Retreatment data beyond six months after surgery were not reported.

##### Holmium Laser Resection of the Prostate (HoLRP)

All three trials of HoLRP used the VersaPulse pulsed holmium laser (Lumenis, Santa Clara, CA, USA). One trial(86) used the Slimline fiber, and the other two(18,120) did not specify the fiber that was used. No published controlled trials have compared the use of different HoLRP devices. In general, however, the devices appear to be the sameor similar in different studies, which supports the grouping of these HoLRP studies.

- One trial reported that HoLRP and TURP improve symptoms to a similar degree and that HoLRP operations take longer than TURP operations. However, HoLRP requires a shorter length of stay and catheterization time than does TURP.

One RCT (N = 120) compared HoLRP to TURP.(18,121,122) At two-year followup, improvements in symptoms after HoLRP were similar to those after TURP.

These authors also reported statistically significantly longer operation times for HoLRP (mean 41.5 minutes) than for TURP (25.3 minutes). However, patients who received HoLRP experienced statistically significantly shorter hospital stays (mean 1.1 days vs. 2.0 days) and catheterization times (0.8 days vs. 1.6 days) than patients who received TURP. The study also reported that two years after treatment, 8% of patients who received HoLRP had required additional surgical treatment as compared to 12% of patients who had received TURP (not statistically significantly different).

- One trial reported that some physiological measures are significantly better after HoLRP than after VLAP, but improvement in symptoms is similar. Catheterization times are shorter after HoLRP than after VLAP.

Two trials compared HoLRP to VLAP.(86,120) Gilling et al. (1998)(120) (N = 22) found that some physiological measures were significantly better after HoLRP than after VLAP, but reported that symptoms and postvoid residual volumes were similar after these two treatments. The trial may not have been sufficiently powered to detect clinically meaningful differences. Both trials reported that catheterization times were significantly shorter after HoLRP than VLAP (1.4–1.9 days versus 9.0–11.9 days, respectively).(86,120)

##### Holmium Laser Enucleation of the Prostate (HoLEP)

Both trials of HoLEP used the VersaPulse holmium laser and VersaCut Morcellator (Lumenis, Santa Clara, CA, USA).

- Two trials reported that after six months, HoLEP and open prostatectomy yield similar symptom improvement in patients with large prostates. Two trials reported that HoLEP required shorter hospital stays and one trial reported that HoLEP required shorter catheterization times.

Trials of HoLEP enrolled only patients with large prostates (>100 grams), and therefore the control group surgical procedure was open prostatectomy. Two controlled trials (N = 140) reported on this comparison.(123,124) At six months, symptoms and physiological measures were similar after HoLEP and open prostatectomy.

Kuntz et al. (2002)(123) reported statistically significant longer operation times for HoLEP than for open prostatectomy (mean 136 minutes versus 91 minutes). Moody et al. (2001)(124) reported a difference in the same direction that was not statistically significant (HoLEP 197 minutes, open prostatectomy 173 minutes). Both trials reported that hospital stay was statistically significant shorter after HoLEP than after open prostatectomy (2.1–2.9 days vs. 6.1–10.5 days).(123,124) One trial reported that catheterization time was statistically significant shorter after HoLEP than after open prostatectomy (1.28 days vs. 8.1 days).(123,124) In addition, fewer HoLEP patients required blood transfusions (0% versus 13–30% for TURP).(123,124)

Both trials reported similar rates of adverse events for HoLEP and open prostatectomy, but few (usually <5) patients experienced any given event. Therefore, the frequencies of adverse events that were reported in these trials may not be reliable.

One trial reported that retreatment rates at six month followup were similar for HoLEP and prostatectomy,(123) but no data from controlled trials are currently available on long-term retreatment rates.

### Interstitial laser coagulation

#### Technology Description and Clinical Issues

In interstitial laser coagulation (ILC), the physician inserts a fiberoptic laser probe through a cystoscope into the prostate at fixed points. Laser energy is applied for approximately three minutes to coagulate each area of obstructing prostate tissue, producing necrosis. In contrast to other laser procedures, where coagulation necrosis occurs at the urethral surface, in interstitial laser coagulation, delivery of laser energy directly into the tissues produces coagulation necrosis inside the adenoma. The postprocedural tissue sloughing that occurs following surface laser treatment does not occur with ILC,(125) which may reduce the risk of urinary tract infection.(126) The treated tissue then cavitates or is absorbed over a period of several weeks.

ILC can be performed in a physician’s office or an outpatient surgery center using local anesthesia and intravenous sedation. The ILC procedure takes approximately 30 to 60 minutes, depending on the number of areas to be treated. Postprocedure catheterization is required for 7 to 21 days. The use of laser energy minimizes the risk of bleeding. However, like most other laser procedures, ILC destroys tissue, not reserving any for histological examination, and thus requires physicians to take pretreatment samples in patients at risk for prostate cancer.(127)

ILC was first developed using the Nd:YAG laser of 1,024 nm, but has since been modified for use with diode lasers of 805 to 980 nm.(126) Standard treatment protocol begins with the laser firing with 20 watts of energy, gradually decreased to about 7 watts. The applicator may allow laser energy to be emitted in all directions, or only circumferentially forward.(126) It is unclear from the small literature base whether these different technologies affect the efficacy of ILC; therefore, we discuss the reported efficacy of ILC as a group, which conforms to the way the procedure is categorized by clinicians in the literature. There are no published controlled trials comparing the efficacy of individual ILC devices. The only application difference that we call out in our discussion is a single controlled trial of low-powered ILC, in which the initial wattage is lower than in the traditional protocol.(128) FDA cleared lasers used in ILC include the Ethicon Indigo 830e and Dornier’s MediLas H. The use of these lasers is generally indicated for men over 50 years old with symptoms of BPH and prostatic lobes sizes of 28–85 cc.

#### Clinical Practice Guidelines

The Fifth ICBPH rated ILC an “acceptable” procedure for BPH.(19) The AUA considers ILC an “emerging therapy” and states that additional data are required before it can be recommended as a treatment option. However, they state that ILC may be offered to appropriate patients provided that the uncertainty of ILC outcomes relative to recommended treatments are discussed with the patient.(3)

#### Findings

Two of the five trials comparing ILC to TURP reported the device used: one trial used the Medilas 4199 Fibertom Nd:YAG laser (Dornier MedTech, Kennesaw, GA USA) at a wavelength of 1,064 nm. Wattage was varied from 20 W down to 7 W.(129) The second trial used the Dornier ITT thermotherapy fiber (Dornier MedTech), from 20W down to 7.5 watts.(127)

The other three studies did not specify what device was employed, but two of them reported starting the treatment at 20 watts.(43,126) Without further information or comparison among devices, we assume that this class of devices can be considered together.

- ILC and TURP generally provide similar improvements in symptoms and quality of life. Results for physiological measures were mixed. Two trials reported higher retreatment rates after ILC. Unlike TURP, ILC may not require any hospitalization time, but this may be offset by a longer catheterization time.

Two RCTs and three non-randomized controlled trials (N = 496) compared ILC to TURP.(43,126,127,129,130) In general these trials reported similar results for ILC and TURP in symptoms (IPSS) and quality of life; however, one study reported that DANPSS symptom and bother scores were higher (worse) after ILC than after TURP.(129) One trial asked patients about satisfaction with treatment: while 56% of TURP patients reported being “completely satisfied,” only 24% of ILC patients reported the same.(129)

Results for physiological measures were mixed; two RCTs found that peak urinary flow (Qmax) was similar after ILC and TURP,(43,129) while two non randomized trials found Qmax to be better improved after TURP (statistical significance not reported).(126,127) One RCT and one non-randomized trial reported that post-void residual volume (PVR) was similar after both treatments,(43,127) while one RCT and one non-randomized trial found that PVR was higher after ILC (statistically significant in the RCT).(126,129)

The two trials that reported retreatment rates for ILC and TURP both found higher rates for ILC (7–16% ILC versus 0–3.5% TURP) (statistical significance not reported).(43,127) However, both studies had a small number of patients in the ILC group (N = 30 to 37), and the overall number of patients undergoing retreatment were very low (<4 per group). This low statistical power may result in unreliable event rate estimates.

Two RCTs reported that ILC had higher rates of urinary tract infections (UTI) (statistical significance not reported), (20–61% ILC versus 11–14% TURP)(43,129) while one non-randomized trial reported that ILC was associated with a lower rate of UTI (7% versus 13% for TURP).(127) Because these were not large trials, estimated event rates may not be reliable, especially for those events occurring with low frequency.

In the three studies reporting hospitalization time (two RCTs and one non-RCT), ILC had a shorter hospitalization time than TURP (and in the United States, may almost always be performed on an outpatient basis(131)),(43,127,129) but one non-randomized trial reported that ILC requires several days of catheterization instead (mean: 14 days versus 3.5 days).(127)

- Two trials reported that ILC and transurethral microwave therapy (TUMT) yield similar symptom improvements, but that ILC provided higher peak urinary flow rates. One RCT also reported that ILC was associated with a higher rate of adverse events than TUMT.

Two trials, Norby et al. (2002) and Arai et al. (2000) (N = 182) compared ILC to TUMT.(129,130) Norby’s randomized trial reported similar symptom improvements for ILC and TUMT at 6 months and slightly more improvement in peak urinary flow rate (Qmax) with ILC (statistical significance not reported).(129) The Arai trial, which was not randomized, reported significantly greater improvements with ILC for symptoms, Qmax and QoL; however, the study was not randomized and had only 3 months’ followup.(130)

Norby reported in general that there were more adverse events after ILC than after TUMT, including UTI (61% versus 30%), re-retention (9% versus 2%), retrograde ejaculation (35% versus 22%), and decreased erectile capacity (29% versus 9%) (statistical significance not reported). In one trial, ILC required a mean of 3 days of hospitalization, versus no hospitalization for TUMT.(129)

- One non-randomized controlled trial reported that ILC resulted in better symptomatic, quality of life, and physiological improvements than radio frequency needle ablation (RFNA).

Arai et al. (2000),(130) (N = 88), was the only trial to compare ILC to RFNA (also known as TUNA®), in a non-randomized prospective trial. After three months, ILC was found to be significantly superior to RFNA in terms of IPSS scores, quality of life, and post-void residual volume. Similar improvements were noted for the two groups in terms of BPH Impact Index and maximum urinary flow. Retreatment rates were not reported.

- One non-randomized controlled trial reported that ILC resulted in similar symptomatic improvements to hybrid laser, and a lower retreatment rate.

Pypno et al. (2000) (N = 142), compared ILC to both hybrid laser (VLAP) and TURP. Only 30 patients were included in the ILC treatment group, which limits the statistical power of this comparison. In looking only at results up to six months when most patients were still enrolled, symptom scores, Qmax, and post-void residual volume were all similarly improved in both groups. After a mean 23 months of followup, more hybrid laser patients required retreatment than did patients receiving ILC (15% versus 7%).(127) No statistical analyses were provided to validate any of the patterns observed.

- One RCT reported that low-energy ILC is not as effective as TURP in terms of symptoms, quality of life, or physiological measures. This one trial also reported that while low-energy ILC has a lower rate of retrograde ejaculation than TURP, UTI rates were similar for the two treatments. One trial reported that catheterization time was longer after ILC.

Martenson et al. (1999)(128) (N = 44) compared ILC using a diode laser to apply low energy (10 watts maximum, device not described) to TURP. Results suggested that low-energy ILC was not as efficacious as TURP in terms of most quality of life, symptoms, and physiological measures. It was associated with a lower rate of retrograde ejaculation (42% versus 75%). Catheterization time was 27 days for ILC versus 3 days for TURP, not offset by the reported hospitalization times (2.3 versus 3.8 days). (However, ILC is almost always performed on an outpatient basis in the United States,(131) therefore these statistics may not be representative of general practice.) Twenty percent of patients (6 patients) were retreated in the low-ILC group, versus 7% (one patient) in the TURP group (not a statistically significant difference in this low-powered trial).

### Hybrid laser techniques

#### Technology Description and Clinical Issues

Hybrid laser procedures involve the use of one or more laser techniques, types, and power settings to treat BPH. For example, one hybrid technique uses non-contact VLAP with an Nd:YAG laser and sidefiring fiber to coagulate prostate tissue followed by CLAP using a contact laser probe to vaporize the tissue. Another hybrid technique uses a KTP laser at 34 W for bladder neck incision followed by Nd:YAG coagulation at 60 W.

Hybrid laser techniques were developed to reduce side effects associated with certain laser wavelengths. Using a KTP/Nd:YAG hybrid technique, for example, allows the surgeon to vaporize sections of Nd:YAG coagulated tissue with the KTP laser to reduce the likelihood of prolonged postoperative urinary retention and catheterization.

These techniques employ the same devices as other laser techniques, thus the same FDA 510(k) clearances for marketing apply.

#### Clinical Practice Guidelines

No current clinical practice guidelines discuss hybrid laser techniques.

#### Findings

Seven controlled trials (N = 961; published in 11 reports) have investigated hybrid laser techniques.(109,112,127,132–139) Four trials compared a hybrid laser technique to TURP, and three trials compared a hybrid laser technique to other surgical procedures.

Three studies(91,109,135) used the ADDstat fiber (Laserscope, San Jose, CA, USA), one(112) used the Urolase fiber (Bard, Covington, GA, USA), one(139) used three different fibers (SideFire, Slimline, and DuoTome SideLite, all manufactured by Lumenis, Santa Clara, CA, USA), and two(127,133) did not report the specific type(s) of laser fibers. Also, the seven controlled trials used six different laser generators; these included the VersaPulse Select laser (Lumenis, Santa Clara, CA, USA),(139) the Nd:YAG/KTP laser (Laserscope, San Jose, CA, USA),(109,135) the KTP/YAG XP laser (Laserscope, San Jose, CA, USA),(137) the Nd:YAG Medilas 4060 Fibertom laser (Dornier, Munich, Germany),(127) the SLT Nd:YAG laser (Surgical Laser Technologies, Oaks, PA, USA),(133) and an Nd:YAG laser from an unspecified manufacturer.(112)

- Hybrid laser techniques are too varied to permit general conclusions about this category of treatment for BPH.

### Comparisons between hybrid laser techniques and TURP

In one trial (N = 100), surgeons first vaporized the prostatic fossa using a KTP laser, and then performed VLAP using an Nd:YAG laser to create craters in the lateral lobes.(109,132,137,138) The authors reported that symptoms, physiological measures, and retreatment rates were similar for the hybrid laser technique and TURP at three to six years’ followup. Two other trials, one randomized and one not, (N = 275) compared outcomes of patients who received TURP to those who received a hybrid technique consisting of VLAP followed by CLAP.(127,133,134) The authors of both trials reported that patients fared better after TURP.

A fourth trial (N = 204) used a hybrid technique with the KTP laser for vaporization and then the VLAP-free paint technique for coagulation, compared to TURP.(112,120) At one year after treatment, authors reported no differences between patients who had this hybrid technique and the patients who had received TURP.

These four trials suggest that the techniques and results for comparison of hybrid laser to TURP have varied too widely to consider the studies as a group to reach conclusions about one “hybrid” technique.

### Comparisons between hybrid laser techniques and other surgical procedures

One trial (N = 31) compared outcomes after TUEVP to those after the KTP/VLAP technique described above, (137,138) and reported similar outcomes at six months with respect to symptoms, physiological measures, and adverse events. However, the authors did report that operation time was shorter for the hybrid laser technique than for TUEVP.

A non-randomized trial (N = 142) compared the perioperative outcomes of a combined technique of HoLAP and VLAP with those of HoLAP alone, and reported shorter catheterization times and lower recatheterization rates for patients receiving HoLAP alone.(136)

One RCT compared VLAP with the Urolase fiber to those after CLAP/VLAP with the Ultraline fiber.(135) Authors reported no significant differences between the two laser techniques at three years after treatment.

As with the comparison to TURP, again this literature demonstrates a wide variety of hybrid techniques that preclude coming to conclusions about hybrid laser treatment as a single group.

### Photoselective vaporization of the prostate (PVP)

#### Technology Description and Clinical Issues

PVP uses a potassium-titanyl-phosphate (KTP) laser at 80 watts to vaporize prostate tissue. PVP has been under investigation for about five years, and the first commercially available PVP laser system for BPH treatment was introduced in early 2002.(140) PVP was developed in response to the side effects associated with the deep tissue coagulation produced by Nd:YAG lasers. KTP laser wavelengths penetrate only 1 to 2 mm, and the vaporization process may help avoid the perioperative side effects (such as tissue sloughing) of other laser surgical procedures. Another potential advantage of PVP is low blood loss, which can be a problem with TURP.

The PVP procedure lasts from 20 to 50 minutes, depending on prostate size, and is performed using local anesthesia, intravenous sedation, or general anesthesia on an outpatient basis or with an overnight stay.(140) PVP has been used to treat prostates up to 120 grams in size.

PVP using the Lyra G Series Surgical Laser System (Laserscope, San Jose, CA) has received FDA 510(k) clearance to be marketed for the treatment of BPH. The approval documentation did not mention specific indications for prostate size.

#### Clinical Practice Guidelines

Since it has only recently been introduced, PVP was not addressed in the Fifth ICBPH, EAU, and AUA guidelines. We identified no other guidelines addressing this technology.

#### Findings

Our searches identified no controlled comparisons of PVP to sham or to other treatments.

## Minimally Invasive Treatments

### Transurethral radiofrequency needle ablation (RFNA or TUNA^®^)

#### Technology Description and Clinical Issues

RFNA (marketed in the United States under the trade name, TUNA®) is a minimally invasive technique that uses low-level radiofrequency (RF) energy to ablate selected areas of prostate tissue. An RFNA system consists of a computerized RF generator and a urethral catheter with two needles at the tip. The needles can be deployed in the urethra independently, and can be positioned at either lateral lobe of the prostate. The RF generator produces a dual 465 kilohertz RF signal that is transmitted through the catheter to each of the needles to deliver energy at a power between 2 W and 15 W, thereby heating the defined tissue area to produce coagulative necrosis. Thermosensors located in the protective nylon shields of the needles and in the side of the catheter tip monitor temperatures at the periphery of the treated area and in the urethra. The TUNA^®^ system has a safety feature that will automatically shut off the RF signal when the tissue impedance exceeds 400 ohms or the urethral temperature exceeds 46 degrees Celsius.(141,142) The amount of tissue ablation is determined by the length of the needles (tissue contact), power delivery, and treatment duration.(143)

RFNA has been used for prostates ranging in weight from 15 to 100 grams.(144) The procedure takes approximately 45 minutes and can be usually performed in a physician’s office or as an outpatient procedure with topical or local anesthesia, although some patients may require additional sedation.(145) Patients are able to return to most normal activities within 24 hours.(146)

Medtronic Corporation manufactures the TUNA^®^ system and is the only company with FDA clearance to market such a system in the United States. It is cleared for use in men over the age of 50 years with prostate volume of 20–50 cc, who are experiencing symptoms due to urinary flow obstruction secondary to BPH.

#### Clinical Practice Guidelines

The Fifth ICBPH has noted that RFNA could become a “treatment of choice” for relieving BPH symptoms in elderly patients at high surgical risk. However, they emphasized that patient selection and degree of obstruction are critical factors, since RFNA appears to be effective for patients with mild to moderate obstruction, but results have been less than satisfactory for patients with more severe obstruction.(19)

In 2001, the EAU concluded that RFNA is a “simple and safe technique,” but does not recommend it as a first-line treatment for patients with BPH due to treatment failure rates.(49) In 2003, the AUA concluded that RFNA is an effective treatment for partially relieving BPH symptoms (though not as effective as TURP), and that the ideal patient has obstructive BPH, predominantly lateral lobe enlargement, and a prostate size of 60 grams or less.(3)

#### Findings

Few details are provided by the available articles on the devices and techniques used to perform RFNA. None of the published trials appeared to use the FDA cleared TUNA® system, and it is not clear whether there are clinically meaningful differences among techniques. Without any direct comparison of techniques, we assume they are similar and discuss all four studies as a group.

Two randomized controlled trials (Bruskewitz et al. 1998; Mostafid et al., 1997) and two non-randomized comparative studies (Arai et al., 2000; Schatzl et al. 2000), (N = 330) compared RFNA (using the TUNA system) to TURP.(63,64,130,147–149)^4^

4 Bruskewitz and colleagues have recently published follow-up data to their 1998 study following patients to five years (Hill et al., 2004), but results beyond two years had a high attrition rate (>30%) and cannot be considered reliable.(150)

Schatzl also compared RFNA to TUEVP, HIFU, and VLAP, while Arai also compared it to ILC and TUMT. However, in both these latter studies, patients were often assigned to a treatment out of personal preference or based on physiological variables; thus, treatment groups may not be comparable. The Schatzl study also has limited statistical power (approximately 15 patients per treatment group), and may not be able to identify clinically significant differences between the groups.

- RFNA results in less symptom and physiological improvement than TURP up to 24 months after treatment, and two trials reported that the two treatments have similar effects on quality of life. One trial reported that decreased ejaculate and retrograde ejaculation occur less often after RFNA than after TURP.

Bruskewitz et al (1998)(147,148) (N = 121) and Mostafid et al. (1997)(149) (N = 50), both randomized controlled trials, found that IPSS scores and Qmax improved significantly more after TURP than after RFNA. In the Bruskewitz trial (1998)(147,148) these differences did not become apparent until 12 months after treatment. One trial reported that quality of life scores were similar; 50% or better improvement in the AUA bother score occurred in 65% (38/59) of RFNA patients and 75% (35/47) of TURP patients (not statistically significant).(147)

The results from the study of Arai et al. (2000),(130) a non-randomized prospective trial (N = 116), generally agree with the findings of the above two RCTs.

All four trials reported some adverse events. In the largest RCT (N = 121), Bruskewitz reported that all adverse events occurred less often after RFNA than after TURP (statistical significance not reported): decreased ejaculate occurred in 13% of RFNA patients and 54% of TURP patients; bleeding occurred in 32% and 100%, respectively; erectile dysfunction in 0% and 13%; and retrograde ejaculation in 0% and 38%.(147,148)

The Mostafid and Schatzl trials enrolled too few patients to provide reliable adverse event rates. They report the occurrence of UTI, dysuria, and urinary retention in the RFNA group, and blood transfusion, UTI, and urinary retention in the TURP group.(64,149) Arai et al. (2000) reported only sexual complications; the authors asked patients about ejaculation after treatment; significantly more patients undergoing TURP had had no ejaculate or severely or moderately decreased ejaculate after treatment (69% vs 46%, statistically significant).(130)

Bruskewitz (1998) reported that operation time was similar for RFNA and TURP (mean 42 and 53 minutes, respectively). All 56 TURP patients required catheterization while only 40% (26/65) of RFNA patients did (statistical significance not reported).(147,148) Hospitalization was slightly shorter for the RFNA group according to Bruskewitz and Schatzl (1–1.5 days for RFNA and 2.1–4.3 days for TURP).(63,64,147,148) More patients in the TURP group required blood transfusions (14%, or 3/22 versus 0%, or 0/20) in the Mostafid trial (statistical significance not reported).(149)

There are not enough data from controlled trials to determine rates of retreatment.

- One non-randomized trial reported that RFNA and TUMT provide similar results, although patients may be more satisfied with RFNA. One trial reports that RFNA is not as effective as ILC.

Two studies (N = 185) compared RFNA to a variety of competing minimally invasive surgeries.(63,64,130) One study by Schatzl (2000)(63,64) (N = 46) compared RFNA to TURP, TUVP, HIFU, and VLAP. However, sample sizes for each treatment group were small (n≤15), so this study may not have had the power to detect statistically significant differences. Patients were also not randomized to treatment, which may have resulted in non-comparable groups.

In another non-randomized trial, Arai et al. (2000)(130) (N = 139) compared RNFA to both ILC and TUMT. Subjective measures improved after both RFNA and TUMT, although physiologic measurements showed no significant change. When asked about satisfaction with treatment, 23 out of 42 (55%) RFNA patients and 8 out of 40 (20%) TUMT patients were “delighted” or “pleased” (statistical significance not reported).

### High-intensity focused ultrasound (HIFU)

#### Technology Description and Clinical Issues

HIFU is a minimally invasive procedure that uses a transrectal ultrasound probe to image the prostate and then heat tissue to 70 degrees to 90 degrees Celsius without harming adjacent healthy tissue. The physician uses ultrasound guidance to position the HIFU transducer and ensure that the prostatic urethra and bladder neck are in the treatment zone. The transducer is designed to rotate laterally to treat seven to nine areas of the prostate. HIFU treatment causes coagulative necrosis of the prostate tissue. In contrast to other treatments, the HIFU device is inserted rectally and so does not contact the prostate or urethra. This eliminates risks associated with device-related urethral and intraprostatic manipulation.

The outpatient HIFU procedure usually takes less than three hours, and is performed under general or spinal anesthesia, or intravenous sedation, depending on the patient. Postprocedure catheterization time ranges from a few days to over a week.

The ultrasound device (Focus Surgery Sonoblate 500) used for HIFU treatment of the prostate is currently under investigation in the United States, and is not approved or cleared by the FDA for marketing.(151)

#### Clinical Practice Guidelines

The EAU does not recommend HIFU for elderly patients.(49) Information about HIFU was not included in the 2000–2001 Fifth ICBPH proceedings. The AUA considers HIFU an “investigational therapy” that should only be offered in the context of a clinical trial.(3)

#### Findings

- Only one study examined HIFU, but it was not randomized, and patients in its groups were not comparable.

A trial by Schatzl et al (2000)(63,64) was the only comparative study of HIFU. It compared HIFU to TURP, TUEVP, VLAP and RNFA. Randomization was attempted, but could not be carried out, because patient characteristics such as prostate size, prostatic calcifications and middle lobes limited the types of patients who could receive the different treatments. The patients who received HIFU tended to have smaller prostates and less severe symptoms than those who received TURP. Results may be influenced by these differences in patients, and are not considered further.

### Transurethral microwave thermotherapy (TUMT)

#### Technology Description and Clinical Issues

TUMT is a nonsurgical, catheter-based treatment that uses radiant microwave heating to ablate prostate tissue. The microwave generator delivers energy through a urethral catheter to heat the prostate tissue to between 45 degrees and 55 degrees Celsius, and the heating process causes necrosis (localized tissue death) of the prostate tissue that is obstructing the urethra. It is performed on an outpatient basis and usually takes about an hour. Postoperative catheterization times can range from a few days to several weeks, depending on the degree of prostatic edema.(6) Because it does not cut out tissue, there is no reserved tissue for histological examination for prostate cancer.

Although all TUMT devices are designed to deliver microwave energy to the prostate via a urethral catheter, currently manufactured devices differ on a variety of technical details. For example, the standard TUMT method, no matter which device is used, generally takes about one hour to perform. However, two devices have been introduced or modified recently to perform the procedure in about 30 minutes.(152,153) There are currently no published controlled trials about the efficacy of these 30 minute protocols. Although it is possible that individual devices and protocols may differ in level of efficacy, there is no published evidence from controlled trials comparing different TUMT devices in terms of patient outcomes.

Another difference among some TUMT devices is their intended patient population. Some manufacturers state that their devices are for patients with “symptomatic” BPH, and work by heating and destroying prostate tissues (e.g., Prostatron 2.0). Other manufacturers state that their devices are for patients with “obstructive” BPH and focus the thermotherapy on the bladder neck where the obstruction occurs (e.g., Prostatron 2.5).(154)

One major delineation between different TUMT devices is the presence or absence of a cooling mechanism. There are four TUMT devices market approved by FDA that incorporate a urethral cooling device that protects the urethra from the extreme temperatures used to destroy prostatic tissue, and are intended to provide a more tolerable level of pain to the patient.(155) These are the Targis® and Prostatron® (2.0 and 2.5), both manufactured by Urologix, Inc., the Prolieve™ manufactured by Celsion Corporation (on which no published data are yet available), and the Urowave® manufactured by Dornier, Inc. (The Urowave is not currently marketed within the United States.) Two other devices marketed within the U.S. (TherMatrx TRX-2000; Prostalund CoreTherm™) do not incorporate a cooling mechanism, under the supposition by the manufacturers that such a mechanism did not achieve its goal of patient tolerance, and as a result requires heavy patient sedation, which has potential side effects. The non-cooling devices are reported to require only light patient sedation.(155)

Grouping TUMT devices based on the presence or absence of a cooling mechanism is a widely accepted classification in the industry. Given the technical differences between cooling and non-cooling devices, we consider the results from trials on these two classes of TUMT device separately.

We discuss the reported efficacy of all cooling devices as a single group, and there is no published evidence from controlled trials that the individual devices differ in any clinically significant way. The same holds true for the non-cooling devices, although less evidence is available on this newer technological approach.

Treatment efficacy may also be affected by the intraprostatic temperature achieved during treatment.(156) The target temperature of the prostate during TUMT has been reported in clinical trials to range from 45 to 55° C. However, details on target or maximum allowed temperature were scarce in the literature, thus precluding us from analyzing results based on this treatment characteristic. There appear to be no trials that have analyzed the target temperature and its effect on clinical outcomes after TUMT.

The wattage used to attain therapeutic prostatic temperatures may also affect the performance of the device, as different devices are designed to use different power levels. For example, while the Prostatron 2.5 can deliver up to 70 watts of energy, the Thermatrx 2000 delivers only 7 watts. The lack of a cooling mechanism in the Thermatrx device may allow it to heat the tissue as quickly to high temperatures as do cooling devices, even though the actual amount of power used is much lower. We were able to locate only a single, non-randomized controlled trial in the published literature (Rivas et al., 2000) that compared higher and lower-wattage devices in terms of clinical outcomes; however, in this study, patients with smaller prostates were more likely to be assigned to the low-power group, and those with large prostates to the high-power group.(157) Thus, these results may be unreliable. Hence, we have no information on how the wattage of the device may affect the outcomes of treatment, and do not analyze results based on energy level.

The specific design and performance characteristics of the antenna used to deliver the microwave energy to the prostate may also play a critical role in achieving therapeutic intraprostatic temperatures during TUMT, and one laboratory study has shown that different device antennas do provide different patterns of energy to the targeted tissue.(156) However, such findings have not been directly linked to clinical outcomes, and therefore such device specifications are not addressed further in our consideration of the evidence on TUMT.

In October 2000, the U.S. Food and Drug Administration issued a hazard warning for TUMT based on reports of thermal injuries that required subsequent colostomies, partial amputation of the penis, or other interventions. According to FDA,(158) these injuries may take hours or days to become apparent, and are a result of incorrect device placement or migration, balloon leakage, failure to pause treatment when the patient signals pain, oversedation of the patient, treatment of prostates larger than those specified in product labeling, and treatment of patients who have undergone pelvic radiation therapy. This warning appears to apply to cooling TUMT devices, which were the most common TUMT devices on the market at the time of the hazard warning. No such adverse events were reported in the clinical trials considered in this report below; however, clinical trials may provide more rigorously controlled treatment methods than are performed in general practice.

#### Clinical Practice Guidelines

In 2001, the World Health Organization Committee on Interventional Therapies recommended the use of TUMT as a minimally invasive treatment alternative for BPH.(38,48) The EAU guidelines recommend TUMT for patients with larger prostates and higher grades of bladder outlet obstruction, and for patients who wish to avoid surgery or who no longer respond favorably to medical management.(49)

The Fifth ICBPH stated that TUMT is a viable BPH treatment that has “gained a firm place in the urologist’s armamentarium.”(19) In addition, the ICBPH highlighted the importance of mapping intraprostatic temperature during TUMT to avoid thermal injury, and that TUMT systems should have some method of assessing temperature during treatment.(19) All FDA-cleared devices considered in the present report have built-in temperature monitors and safety shut-off mechanisms intended to prevent unnecessary thermal damage.

The AUA concluded that TUMT is effective in partially relieving BPH symptoms, and that no commercial device is superior to another, because their literature searches found no direct comparator trials of commercial devices.(3) ECRI concurs that no such comparison trials are available currently in the published literature, up to May 2003.

#### Findings

Here, we present results from trials of cooling and non-cooling devices separately, as this is an accepted delineation in the industry, and because no other clinical data exist that would support an alternative approach for examining differential efficacy of the devices. We focused on trials that provided technical information about the devices they used, or used a device approved for marketing by FDA. We do not discuss studies that did not identify the type of device used.(159–167)

Thirteen of the 15 relevant controlled trials we identified randomized patients to treatment groups (RCTs),(129,159,168–179) and two were non-randomized controlled trials.(130,157)

##### Cooling TUMT

- Cooling TUMT leads to improved symptoms and physiological measures up to 12 months after treatment.

Five sham-controlled trials (N = 674), all of which blinded patients to treatment, evaluated TUMT devices that employed a urethral cooling mechanism (Targis; Prostatron; Urowave).(159,168–172) All trials were randomized. Four (N = 554) found cooling TUMT to be significantly more effective than a sham treatment in terms of symptoms and physiological measures.(159,168–171) Results on TUMT’s effects on quality of life were mixed. A fifth trial (Nawrocki et al., 1997, N = 120) found similar results on all outcome measures for the sham and TUMT groups. Through an analysis with an additional no-treatment group, the authors attributed many improvements exhibited by both the TUMT and the sham groups to a placebo effect.(172) Improvements may also have been due to the placement of the catheter by itself.

Although individual devices may differ in technical specifications, it appears from the above trials that cooling TUMT devices show the same general trend of results.

Given that cooling TUMT has been found to be generally more effective than a sham treatment (although the precise reason for its efficacy is unclear), it is important to determine whether it offers any advantages over TURP, the current standard of care. The most obvious advantage of TUMT is that it is performed on an outpatient basis under mild sedation. Thus, TUMT is initially less invasive than TURP in the patient’s daily life.

- Most trials report that cooling TUMT provides less symptom relief and less improvement in physiological measures than does TURP. One trial reported that retrograde ejaculation was less common after TUMT than after TURP. Retreatment rates may be higher after cooling TUMT than after TURP.

Five RCTs and one non-randomized controlled trial (N = 514) compared cooling TUMT to TURP.(129,130,173–176,180–182) Three trials on recent models of the Prostatron(129,173,174,180–182) (N = 267) reported that symptoms improved significantly less after TUMT than after TURP. In one trial, more TURP patients expressed satisfaction with treatment after six months (54% vs 16% for TUMT).(129)

However, two older trials (N = 132) using earlier versions of Prostatron(175,176) found TURP to be more effective than TUMT on physiological outcome measures such as Qmax, but reported that the two technologies resulted in similar scores most symptom scales, such as IPSS and Madsen-Iverson.

Adverse events may be more severe after TURP than after cooling TUMT; however, the only device for which adverse event data are available is the Prostatron. Ahmed et al. (1997) reported that more TURP patients experienced retrograde ejaculation after treatment than did TUMT patients (63% versus 22%).(175) Dahlstrand et al. (1995) reported more “late complications” after TURP than after TUMT (13% versus 0%).(176) Norby et al. (2002)(129) reported that the most common adverse event for TURP or TUIP was retrograde ejaculation (50% of patients questioned) and for TUMT, UTI (30% of patients evaluated).

Three trials evaluating Prostatron 2.0 (60W) or 2.5 (70W) reported that retreatment rates may be higher after cooling TUMT than after TURP.(174,176,180) At 36 months, Floratos et al. (2001) employed Kaplan-Meier statistics to estimate the retreatment rate to be 20% for the TUMT group and 13% for the TURP group (not statistically significant).(180) At 30 months, D’Ancona et al. (1998) reported a similar pattern, with retreatment rates of 26% (8/31) for the TUMT group and 10% (2/21) for the TURP group (statistical significance not reported).(174) At 24 months, Dahlstrand also reported that retreatment rates tended to be higher after cooling TUMT (11%, 4/37 patients) than after TURP (0/32 patients) (statistical significance not reported).

- One trial reported that cooling TUMT yielded more improvements in symptoms, quality of life, and peak urinary flow rate than alpha-blockade medication.

In a single randomized controlled trial (N = 103), Djavan et al. (2000)(179) compared cooling TUMT using the Targis device to the alpha-blockade drug, Terazosin, given in increasing doses (from 1 to 5 mg) for 24 days. Patients in this trial had moderate to severe LUTS. The authors postulated that TUMT might provide a viable treatment to delay symptom onset compared to alpha blockades, which have side effects. Over six month followup, patients showed greater improvements in the TUMT group as measured by symptom scales (IPSS), quality of life, and peak urinary flow rate. The actuarial failure rate was significantly lower in the TUMT group (6% versus 41%). Adverse events experienced by patients undergoing TUMT included UTI and loss of ejaculate (exact rates not reported). The Terazosin patients experienced dizziness, asthenia, and headaches (exact rates not reported).

- Two trials provided mixed results as to the relative efficacy of cooling TUMT compared to ILC, suggesting that TUMT is either equally effective or less effective than ILC. One trial reported that fewer patients were satisfied with cooling TUMT treatment than with ILC or RFNA.

One RCT (Norby et al. 2002) (N = 94) compared cooling TUMT using the Prostatron 2.0 device to ILC, and reported similar improvements in symptoms, quality of life, and physiological measures.(129) In a non-randomized trial, Arai et al. (2000) (N = 88) compared cooling TUMT (using the Dornier Urowave) to interstitial laser coagulation ILC) and radiofrequency needle ablation (RFNA, or TUNA^®^); ILC appeared to provide more favorable results than TUMT on all reported outcome measures. Results were similar for RFNA and TUMT, although more RFNA patients were satisfied with treatment (55% versus 24%).(130) Significantly more ILC patients than TUMT patients reported being “delighted” or “pleased” (74% versus 24%).(130)

##### Non-Cooling TUMT

- One RCT reported that non-cooling TUMT may improve symptoms but has associated adverse events.

One published blinded, multicenter RCT (Albala et al., 2000) (N = 190) compared a non-cooling TUMT device (TherMatrx 2000) to a sham treatment.(177) Non-cooling TUMT improved symptoms more than did sham treatment, but was also accompanied by certain adverse events, including bladder spasm (4.1%), gross hematuria (9.1%), and a need for recatheterization (16.8%patients).(177)

- One RCT reported that non-cooling TUMT and TURP yield similar improvements in symptoms and physiological measures, and each has different adverse events.

Wagrell et al. (2002)(178) compared non-cooling TUMT to TURP (N = 146). They found that TUMT and TURP provided similar results in all symptom and physiological measures after 12 months. TUMT patients experienced less hematuria (13% versus 39% of patients) and transient incontinence (3% versus 13%) than TURP patients, but more micturition urgency (37% versus 13%) that continued up to 12 months. Catheterization time was longer for TUMT than for TURP (14 versus 3 days), but this is offset by the lack of hospitalization time with TUMT (0 versus 5 days).

### Transurethral thermotherapy (TUT)

#### Technology Description and Clinical Issues

Thermotherapy is distinguished from hyperthermia by the maximum temperature achieved.(3,183) In thermotherapy treatments, prostate temperatures range from 45 degrees to 60 degrees Celsius; in thermotherapy treatments, temperatures range from 41 degrees to 44 degrees Celsius. Tissue coagulation is known to occur at temperatures greater than 45 degrees to 50 degrees Celsius, but no clear prostate tissue effects have been demonstrated for temperatures below 45 degrees Celsius.(3)

Transurethral thermotherapy appears to be a precursor to the development of transurethral microwave thermotherapy, and was reported on in two controlled trials in 1991.(184,185) No technical details were provided in either trial, and the term “transuretheral thermotherapy” has not been used in the published literature since.

#### Clinical Practice Guidelines

The term “transurethral thermotherapy” is not mentioned in any current clinical practice guideline. The current technology used is transurethral microwave thermotherapy (TUMT), which is covered in a separate section of this report.

#### Findings

Because this treatment is outdated, we do not further consider the results of controlled trials on it.

### Transrectal hyperthermia (TRH)

#### Technology Description and Clinical Issues

Hyperthermia is distinguished from thermotherapy by the maximum temperature achieved.(3,183) In hyperthermia treatments, prostate temperatures range from 41 degrees to 44 degrees Celsius; in thermotherapy treatments, temperatures range from 45 degrees to 60 degrees Celsius. Tissue coagulation is known to occur at temperatures greater than 45 degrees to 50 degrees Celsius, but no clear prostate tissue effects have been demonstrated for temperatures below 45 degrees Celsius.(3)

Transrectal microwave hyperthermia (TRH), also called localized deep microwave hyperthermia, uses a rectal applicator to heat prostate tissue to 42 to 44 degrees Celsius. The applicator is connected to a microwave generator (915 MHz, 20–60 W). A cooling system is used to control rectal wall temperature, and a computer system is used for data collection and analysis. Urethral temperature is monitored using a thermosensor contained in a specially designed urethral catheter, and rectal temperature is monitored using a thermosensor in the microwave applicator. During treatment, the maximum prostate temperature is continuously monitored using the rectal and urethral measurements.

Transrectal hyperthermia is performed on an outpatient basis and does not require sedation or anesthesia. Treatment lasts approximately 60 minutes and requires multiple sessions, usually once or twice weekly for several weeks. Transrectal hyperthermia is typically delivered in 6 to 10 sessions. However, clinical studies have reported delivery ranging from 3 to 18 treatment sessions.(186–188)

Transrectal hyperthermia was under investigation for BPH treatment up to the early to mid 1990s for patients who refused surgery or were at risk for surgical complications. Two controlled trials compared TRH to transurethral thermotherapy,(184,185) while one of these trials also compared it to a prostatic wall stent and prostatic spiral stent.(185) However, no controlled trials were ever published evaluating TRH relative to TURP or any other established treatment method. Although it has applications in treating cancer, transrectal hyperthermia is considered an outdated treatment for BPH.(183)

#### Clinical Practice Guidelines

Transrectal hyperthermia is not included in any current BPH clinical guidelines. It is therefore not considered further in this evidence report.

#### Findings

Because this treatment is outdated, we do not further consider the results of controlled trials on it.

### Balloon dilation

#### Technology Description and Clinical Issues

Balloon dilation for BPH is similar to balloon angioplasty for coronary artery disease. A balloon is inserted into the prostatic channel, guided by a scope or the surgeon’s finger, and then inflated. The inflation results in the tearing of prostate gland tissue, which allows passage of urine. Balloon dilation had been considered an alternative to open prostatectomy for the past several years, but has been abandoned because patients often have symptom recurrence and require retreatment within two years. In addition, the procedure is not effective for patients with larger prostate glands.(189)

#### Clinical Practice Guidelines

In a 1997 guideline, the World Health Organization classified balloon dilation as an unacceptable treatment for BPH.(190) The ICBPH has rated balloon dilation as an unacceptable treatment since 1995.(19) The AUA states that balloon dilation is “not recommended” for treatment of BPH.(3)

#### Findings

Because this treatment is outdated, we do not further consider the results of controlled trials on it.

### Water-induced thermotherapy (WIT)

#### Technology Description and Clinical Issues

In WIT, also called balloon thermoablation or liquid ablation, heated water is circulated through a balloon that spans the prostatic urethra. There is a console heating system that heats and maintains water temperature at a chosen temperature between 60 or 70 degrees Celsius, and a peristaltic pump that continuously circulates the water. Usually, WIT protocols use water heated to 60 or 62 degrees Celsius. The circulating water inflates the balloon and conductively heats the prostate tissue, thereby causing coagulation necrosis. During WIT, urethral and rectal temperatures are monitored using temperature sensors. Because the treatment balloon length and catheter length are available in nine lengths, WIT can be used to treat prostates of varying sizes.(191)

WIT can be performed on an outpatient basis with local analgesia (lidocaine gel). The procedure takes approximately 45 minutes. In clinical studies, long catheterization times (weeks) or placement of temporary urethral stents were necessary. WIT is not considered an alternative to TURP in patients who can undergo TURP.(191) Rather, it is an option for patients at high risk for surgical complications, such as cardiopulmonary problems, or for patients who may require a less invasive treatment.

Although the device (Aquatherm, ACMI; previously Thermoflex, ArgoMed) is FDA-cleared for marketing, WIT is still being researched, since few clinical studies have been published and the protocol (treatment time and temperature) have not been supported by adequate pathologic studies.(192)

#### Clinical Practice Guidelines

In 2000, WIT was added to the list of interventional therapies evaluated by the ICBPH. The Fifth ICBPH noted that preliminary results of WIT are encouraging, but that further research is needed before clinical acceptance.(19) The AUA considers WIT an “emerging therapy” and states that additional data are required before WIT can be recommended as a treatment option. WIT can be offered to appropriate patients, provided outcomes relative to recommended treatments are discussed with the patient.(3)

#### Findings

Our searches identified no controlled comparisons of water induced thermotherapy (WIT) to controls or to other treatments.

### Transurethral ethanol ablation

#### Technology Description and Clinical Issues

Transurethral ethanol ablation, also called absolute ethanol injection, transurethral injection therapy, or chemoablation, involves the injection of absolute alcohol into the prostate lobes. A physician inserts an endoscopic injection device into the urethra via a cystoscope. The needle tip is pushed through the urethral wall into the prostate tissue and alcohol is injected at two to five points, depending on the size of the prostate. The injection induces sclerosis and necrosis of the obstructing prostate tissue.

Transurethral ethanol ablation is an outpatient procedure usually performed in about 30 minutes with local anesthesia and/or intravenous sedation. Postprocedural catheterization for one to two days is required. Minor side effects include dysuria and hematuria.

In 1998 and 2000, endoscopic injection devices received FDA clearance for the injection of biomaterials into the urethra and lower urinary tract. However, the use of absolute alcohol for BPH has not received specific approval and is currently in clinical trials.(193) The AUA considers ethanol treatment an “investigational therapy” and states that it should not be offered outside the context of a clinical trial.(3)

#### Findings

Our searches identified no controlled comparisons of ethanol ablation to controls or to other treatments.

### Prostatic stents

#### Technology Description and Clinical Issues

Prostatic stents are spring- or coil-shaped wire devices placed in the prostate channel to keep it open. The stent’s insertion into the prostatic urethra pushes away obstructive tissue. Stents do not normally compete with surgical procedures and all of the less invasive devices, rather stents are typically used for patients who are not candidates for the other procedures and devices. Stent insertion takes approximately 30 minutes under local anesthesia. Thus, stents have been used in patients who cannot tolerate a surgical procedure with general or regional anesthesia due to another medical condition. Stents are most commonly inserted in frail, elderly patients.(194) Problems associated with the use of these stents include irritation and debris accumulation around the stent, stent migration, and increased incidence of urinary tract infections.

As of July 2003, one prostatic stent (Urolome™) was FDA approved for marketing for treatment of symptoms secondary to BPH. The approved BPH –related indications are to relieve prostatic obstruction secondary to BPH in men at least 60 years of age, or men less than 60 years of age who are poor surgical candidates, and whose prostates are at least 2.5 cm in length. A contraindication is fracture distraction defects of the posterior urethra. The device is not intended for temporary use.

#### Clinical Practice Guidelines

The AUA 2003 guidelines suggests that “because prostatic stents are associated with significant complications, such as encrustation, infection and chronic pain, their placement should be considered only in high-risk patients, especially those with urinary retention.”(3) The ICBPH has classified prostatic stents as acceptable with restriction since 1993.(5,19) According to the Fifth ICBPH, prostatic stents have been successfully used in patients at high risk for anesthesia-related complications or who have a short life expectancy, and the ideal patient is frail, elderly, and suffering from urinary retention.(19)

#### Findings

- One retrospective study reported that fixed stents provide more symptom relief and greater improvements in peak urinary flow rates than spiral stents, TUT or TRH.

There was one nonrandomized, unblinded, retrospective comparison (Montorsi et al., 1994)(185) among groups of 30 patients who chose a fixed stent (Urolome Wallstent, American Medical System), a spiral stent (Urologische Spirale, Uromed), TUT (Prostatron, Technomed), or TRH (Prostathermer 99D, Biodan Ltd.). All of the patients were poor surgical risks because of previous cerebrovascular accidents, myocardial infarction, coagulation disorders, or obstructive pulmonary disease. Contraindications to these treatments were considered to be a prominent median lobe, prostate or bladder cancer, calculi, neurogenic bladder, or stricture. The patients in the four groups appeared to be fairly well matched in BPH Boyarsky symptom scores and physiological measures. Stents provided better results for symptoms (statistically significant) and slightly better flow rates (not statistically significant) at 12 months. Also, the fixed stent provided significantly better flow rates and symptom scores than the spiral stent. Quality of life, adverse events, perioperative events, and retreatment rates were not reported.

- One RCT reported that ILC plus a postoperative stent led to similar physiological outcomes and rates of adverse events as ILC alone. This trial reported that the addition of the stent allowed resumption of voiding sooner after ILC.

A randomized comparison of ILC vs. ILC with stent(195) reported that no differences in physiological outcome measures were observed with or without the stent. Adverse event rates were similarly low for both treatment groups.

Use of a stent allowed almost twice as many patients to start voiding on the first day following the operation (81% versus 43%). With the stent, the mean for start of voiding was 1.5 days, compared to over 6 days without the stent (statistically significant).

- One trial reported that both a fixed stent and self-expanding stent cause high rates of transient irritative symptoms. The authors did not report major treatment-efficacy related outcomes.

One trial (randomization not reported) compared a first-generation fixed-caliber stent to a second-generation self-expanding large caliber stent.(196) Short-term irritative symptoms were the primary adverse event experienced by most patients in both the fixed and self-expanding stent groups (80% and 90%, respectively). Correct positioning of the stent was more likely to be achieved in the expanding stent group (100% versus 83% in the fixed group).

The authors did not report any outcomes relating to symptoms, physiological measures, quality of life, or retreatment. Lack of data renders it difficult to evaluate the comparative efficacy of these two types of stents.