# Methods

## Literature Search

To obtain information for this technology assessment, we searched 17 electronic databases (including Medline and Embase) for relevant articles. These searches were specifically designed to locate all controlled trials of treatments for BPH published since 1975. The full list of databases and search strategies is in Appendix C. Searches were conducted in November 2002, and updated in January and May 2003. We also examined the bibliographies of relevant publications. These searches yielded a total of 1,811 citations.

## Selection Criteria

We read each abstract and applied a priori inclusion criteria (Table 2) to determine whether to retrieve the full article. We developed these criteria in consultation with The Agency for Healthcare Research and Quality (AHRQ). If the abstract left doubt about whether the article met the inclusion criteria, it was retrieved and the determination about whether to include it was made from the full text. A total of 344 articles were retrieved from the literature searches and reference lists in other articles. To avoid double-counting of patients, we extracted only unique data from multiple publications of the same trial.

Table 2 Study inclusion criteria

Category | Inclusion Criteria
Publication date | 1975 through December 2002. Treatments for BPH have changed greatly since 1975, and the results of treatments before 1975 are less relevant to patients than more recent treatments.
Publication type | Full articles. The only exception to this was the inclusion of relevant abstracts presented at the May 2003 meeting of the American Urological Association. These abstracts were not included in figures or evidence tables, and our discussion of them is restricted to the text in the relevant section of the report.
Study design | Any controlled trial with at least 10 patients per group. We included controlled trials even if they were nonrandomized, historically controlled, matched controlled, retrospective controlled, or any other type of reasonably-matched comparative design. Single group studies were not included because of the known placebo and regression effects of treatments for BPH (see discussion in the earlier section on descriptions of outcomes).
Participants | Men with symptomatic BPH.
Treatments | Any treatments for men with BPH that have been published in controlled or comparative studies. This includes all of the treatments discussed in this report. The historical surgical standard of TURP was included only if it served as a control for one of the other treatments of interest.
Control treatments | Standard surgeries such as TURP, TUEVP, open prostatectomy and TUIP, as well as placebo, sham surgery, medication, watchful waiting, or no treatment. Studies of the historical standards of watchful waiting and medication were included only if they served as controls for one of the other treatments of interest.
Outcomes | We set no restrictions regarding the reporting of outcomes, because all outcomes were considered relevant.

## Evidence Base

Applying the study selection criteria yielded 164 articles. We excluded 19 of these articles for reasons listed in Appendix D. Thus, the evidence base consisted of 145 articles reporting on 104 separate studies.

## Data Extraction

Three methodologists extracted information from the included trials. This information included not only outcome results, but also study location, randomization, whether a trial was prospective, blinding of patients, blinding of raters, intention-to-treat analysis, and patient inclusion criteria.

Based on the recommendations of AHRQ, we extracted all reported measures at all reported time points after surgery. This allowed us to identify trends in data, and to empirically determine whether data at earlier time points indexed treatment success as reliably as data gathered at later times. If data were reported in figures but not in text, ECRI estimated them from the figures. When study authors did not report dichotomous data as percentages, ECRI computed percentages. All extracted information, including author errors and reporting discrepancies within and between publications, is noted in the Evidence Tables.

Two additional methodologists audited all of the information entered into evidence tables from 51 of the 104 studies (49%). These 51 studies were randomly selected using a SAS random number generator. The error rate was less than 0.5%. These errors were subsequently corrected, so the total error rate, including data entry and typographical errors, in the final evidence tables is less than 0.25%.

The evidence tables for all studies and all outcomes are found in Volume II of this report. Definitions of treatment acronyms, as well as definitions of abbreviations that are in the Evidence tables, appear in Appendix E.

## Analytic Approach

This report takes the form of a systematic narrative review. Evidence tables (Volume II of this report) provide an essential tool for distilling and organizing the most important information from the published clinical trials. From these tables, ECRI identified the most clinically relevant trials, organized the discussion of the results, and formulated conclusions.

Inasmuch as there were many studies of similar quality for some technologies, it was not always possible to select the “best” study for discussion and analysis. Therefore, ECRI considered the results across all relevant controlled studies wherever appropriate, giving greater weight to studies of larger size, longer followup, and higher quality.

There is not space herein to provide the numbers and full reasoning behind all of the conclusions, and the reader is directed to the evidence tables on which all of the conclusions were based.

Figure 1 shows the analytic framework for this report. Patients with symptomatic BPH may have mild symptoms and thus may receive no treatment or medical management. Patients with moderate or severe symptoms that cannot be controlled through medical management may receive one of the many alternative treatments that are the focus of this report. The choice among these alternatives can be influenced by many factors including prostate size, availability of treatments at the treating institution, expertise of treating physician, and patient preference. TURP is considered the “gold standard” treatment for BPH, but less invasive treatment alternatives may be attempted first to avoid or postpone TURP (as discussed in the Introduction section).

Among the outcomes measured after treatment, some are intermediate outcomes (physiological measures of urinary tract function such as peak urinary flow rate), whereas others are patient-oriented (symptoms, quality of life, adverse events, perioperative measures, and retreatment)^1^. The patient-oriented outcomes are more important than the intermediate outcomes because they more directly measure what matters to patients. Also, the relationship of the physiological measures to the symptoms is complex and poorly understood. Retreatment is a key outcome because it is a marker for treatment failure, and because a major rationale for the less invasive treatments is to avoid TURP. Alternatives to TURP may be associated with fewer adverse and perioperative events, but patients who receive them may be more likely to require retreatment due to insufficient resolution of symptoms. Therefore, the decision to use a new treatment may involve deciding if the tradeoff between adverse effects and efficacy is acceptable, rather than a simple decision on whether the treatment has equal efficacy with TURP. For each treatment in the Results section, we considered all of the above types of outcomes.

1 All outcome categories are further described in Table 1 of the Introduction and in Appendix A.

Figure 1 Analytic Framework