# Introduction

## Purpose of Report

The aim of this report is to provide CMS with an overview of surgical and minimally invasive procedures for the treatment of benign prostatic hyperplasia (BPH). Medical therapy is not considered in this report, except when it served as a control group. The specific purposes of this report are to:

- Review the relevant health outcomes for surgical and minimally invasive treatments for benign prostatic hyperplasia (BPH)
- Review the literature on patient utilities for outcomes of treatments for BPH
- Describe the surgical and non-surgical options for the treatment of BPH, including a narrative review of technical issues associated with each option, potential adverse effects and training issues
- Conduct a systematic narrative review of the clinical literature comparing the alternative surgical and less invasive treatment options to transurethral resection of the prostate (TURP), and to each other where possible, with attention to data on beneficial and adverse effects.

## Background

Benign prostatic hyperplasia (BPH) is a condition primarily of middle-aged and elderly men. Frequency of the condition increases with age, and it is found in the majority of very elderly men. Consequently, surgical and medical treatments for BPH are some of the most common therapies administered in all of medical practice.(1,2)

BPH is a complicated condition. It can be associated with bothersome lower urinary tract symptoms (LUTS) that affect quality of life and sleeping patterns. LUTS, which may include urgency to urinate, frequent urination, weak stream, straining, and/or the sensation of incomplete bladder emptying, are usually the chief complaints of patients with BPH.(3) In the most severe stage of BPH, the inability to completely empty the bladder may progress to complete urinary blockage, which can in turn lead to kidney damage.(4)

LUTS may be also accompanied by bladder outlet obstruction (BOO), and these conditions may be caused by histologically-confirmed BPH, an enlarged prostate gland, or other causes. The Fifth International Consultation on BPH of 2001 (ICBPH) recommended that the general term LUTS be used until there is more knowledge of the causative association of BPH with particular symptoms.(5) However, only a few recent trials have followed this recommendation. Most trials used the term BPH as a general term encompassing all of the above terms, and many of the trial publications did not offer very specific definitions of BPH. Therefore, throughout this document, we use BPH as a general term for all of the above concepts.

In recent years, surgical treatment of BPH has been increasingly replaced with medical management, which can improve mild to moderate symptoms and slow the progression toward severe symptoms. However, medication may have undesirable side-effects, and may not provide adequate relief for chronic severe BPH. In such cases, surgery or minimally invasive procedures may be offered.

Transurethral resection of the prostate (TURP) is the standard surgical treatment for chronic severe BPH, although open prostatectomy may be required for men with very large prostates.(4) Transurethral electrovaporization of the prostate (TUEVP) is a procedure related to TURP that uses much of the same equipment and skills, and has come to be considered by some a standard variation of TURP. Likewise, transurethral incision of the prostate (TUIP), a less radical procedure that slices through prostate tissue rather than removing it, has also come to be considered by some a surgical standard, but limited to men with small prostates.(6)

These standard surgical procedures, however, can result in blood loss requiring transfusion, reaction to irrigation fluids (TURP syndrome),(7–11) incontinence, impotence, cardio-pulmonary events, stroke, and even death.(2,12–16) These procedures also involve regional or general anesthesia, with their inherent potential complications, a hospital stay of 1.5 days or more, as well as catheterization during one or two days of recovery. In recent years, less invasive alternatives have been explored that will minimize or altogether avoid these undesirable results.(17) Therefore, the major purpose of this report is to compare these newer less invasive technologies to TURP and its variants.

### Prostate cancer detection

There can occasionally be an overlap of symptoms between prostate cancer and BPH; therefore, prostate cancer is typically investigated in the diagnostic workup of LUTS and BOO. TURP is not a diagnostic test for prostate cancer, but one advantage that it does provide while treating LUTS is that it provides tissue for histological detection of prostate cancer. This leads to early detection of some incidental cases of prostate cancer, as well as some clinically irrelevant cases. With the advent of less invasive devices and procedures for LUTS treatment that do not provide prostate tissue samples, there was concern that some incidental cases of prostate cancer could go undetected. Prostate cancer detection currently relies primarily on prostatic specific antigen (PSA) and transperineal prostate biopsies, which to some extent has allayed such concerns. Nevertheless, pretreatment PSA assays and biopsies may miss some prostate cancers that are detected at TURP.(18)

The importance of this prostate cancer detection issue and whether, or to what extent, it should influence the choice of treatment for BPH is unclear. However, the Fifth ICBPH advised that this issue be considered in men with more than ten years’ life expectancy when choosing a treatment for BPH.(19) Importantly, such younger men are often considered for less invasive treatments with potentially fewer sexual side effects; and many such procedures retain no tissue for biopsy sampling. Resolution of this prostate cancer diagnostic issue is beyond the scope of this technology assessment, nevertheless, where appropriate, we mention the availability of prostate tissue samples in our descriptions of the various surgeries and less invasive treatments for BPH.

## Outcome measures

Several different types of outcome measures are important when evaluating BPH treatment efficacy, and we discuss each of them when considering each treatment. Table 1 below outlines these different categories of outcome measures and provides examples of each.

Table 1 Description of Outcome Measures

Outcome measure category | Description | Examples
Symptoms | Patient’s subjective experience of having BPH. Obtained using questionnaires completed by patients. | International Prostate Symptom Score (IPSS)(20) Madsen-Iverson Scale(21)
Quality of life | Patient’s ability to perform daily functions and enjoy life, including cognitive abilities, activities of daily living, and family relationships. Questionnaires may relate specifically to BPH or be more generalized. | Short Form 36 (SF-36) BPH Impact Index IPSS QoL Score
Physiological measures | Patient’s physiological status as it relates to BPH, including measures of prostate size and urine flow. Does not reflect patient experience. | Peak flow rate (Qmax) Post-void residual urine volume (PVR) Voided volume
Retreatment rate | Proportion of patients requiring or requesting another treatment after undergoing the treatment in question. Usually calculated a number of weeks or months after treatment.
Adverse events | Harmful outcomes experienced after treatment, primarily physiological. | TURP Syndrome Retrograde Ejaculation
Perioperative outcomes | Outcomes that occur during or shortly after the treatment. | Procedure time Blood loss Hospitalization time

Further discussion of these outcome measures, including a discussion of advantages and disadvantages of each, is provided in Appendix A.

Patients do not view the outcomes listed in Table 1 as equally important, and different patients may perceive any single outcome differently. For example, one patient might quite negatively perceive having to get up at night to urinate, but another might not be bothered by this symptom. The notion that different patients can have different opinions about the same outcome has sparked interest in utility assessment in patients with BPH. Using utilities, a patient can express his opinions about the relative values of different outcomes. The available data on BPH patients’ utilities are sparse: only two low-powered studies have reported such data.(22,23) Ackerman et al. (2000)(22) found that patients perceived severe incontinence and urinary retention to be the worst among the assessed long-term outcomes. Schulz et al. (2002)(23) reported that the typical patient was willing to give up 14%–20% of his lifespan in order to relieve his BPH symptoms. Background about utilities, as well as detailed tables of published utility data, appear in Appendix B.