# Conclusions

Benign prostatic hyperplasia (BPH) primarily affects some middle-aged and very many elderly men. Consequently, surgical and medical treatments for BPH are some of the most common therapies administered in all of medical practice. The “gold standard” treatment for BPH is transurethral resection of the prostate (TURP). In recent years, there has been a search for less invasive alternatives that will minimize or altogether avoid some of the undesirable aspects of TURP.

A purported advantage of the minimally invasive approach to treating BPH is that such procedures have fewer side effects compared to TURP. However, the published literature of controlled trials does not report adverse event rates uniformly and comprehensively when comparing minimally invasive procedures to TURP. Because some of these procedures do not appear to be as effective as TURP in relieving symptoms (see bullets, below), a clear advantage in the incidence of adverse events would be essential in order to recommend such procedures.

- Standard surgical alternatives to TURP include transurethral electrovaporization techniques (TUEVP and TUVRP), open prostatectomy, and transurethral incision of the prostate (TUIP).
- Because electrovaporization involves skills and devices similar to those used in TURP, it can be considered a modification of TURP. Symptoms and peak urinary flow rates are similar after TUEVP, TUVRP and TURP. Quality of life is also similar after TUEVP and TURP. Both hospitalization time and catheterization time are shorter for TUEVP.
- There are no current direct comparisons of open prostatectomy to TURP. Open prostatectomy and TURP are now used on different patient populations. Open prostatectomy is the preferred treatment approach for men with large prostates.
- TUIP is recommended for men with small prostates. TUIP and TURP provide similar symptom relief. TUIP results in lower retrograde ejaculation rates and shorter operation times, as well as shorter catheterization times and hospital stays than TURP. However, TURP results in higher peak urinary flow rates than TUIP.
- CLAP and TURP resulted in similar improvements in physiological measures. CLAP and TURP provided similar symptom relief and similar quality of life improvements in most trials, but one double-blinded RCT found these outcomes to be less improved after CLAP than after TURP. CLAP results in less blood loss than TURP.
- One year after surgery, symptoms and quality of life improvements are similar after VLAP and TURP. VLAP requires shorter hospitalizations and longer catheterization times than TURP. Two trials report that major adverse events are less likely after VLAP than after TURP. Three trials report that patients who receive VLAP are more likely to require retreatment than patients who receive TURP.
- One controlled trial reported that symptoms and physiological measures improve to a similar degree after HoLAP and TURP. This RCT also reported that HoLAP operations take longer than TURP operations.
- One trial reported that HoLRP and TURP improve symptoms to a similar degree and that HoLRP operations take longer than TURP operations. However, HoLRP requires a shorter length of stay and catheterization time than TURP.
- Two trials reported that after six months, HoLEP and open prostatectomy yield similar symptom improvement in patients with large prostates. Two trials reported that HoLEP required shorter hospital stays and one trial reported that HoLEP required shorter catheterization times.
- ILC and TURP generally provide similar improvements in symptoms and quality of life. Results for physiological measures were mixed. Two trials reported higher retreatment rates after ILC. Unlike TURP, ILC may not require any hospitalization time, but this may be offset by a longer catheterization time.
- Hybrid laser techniques are too varied to permit general conclusions about this category of treatment for BPH.
- RFNA results in less symptom and physiological improvement than TURP up to 24 months after treatment, and two trials reported that the two treatments have similar effects on quality of life. One trial reported that decreased ejaculate and retrograde ejaculation occur less often after RFNA than after TURP.
- Only one study examined HIFU, but it was not randomized, and patients in its groups were not comparable.
- Cooling TUMT leads to improved symptoms and physiological measures up to 12 months after treatment. Most trials report that cooling TUMT provides less symptom relief and less improvement in physiological measures than does TURP. One trial reported that retrograde ejaculation was less common after TUMT than after TURP. Retreatment rates may be higher after cooling TUMT than after TURP.
- One RCT reported that non-cooling TUMT may improve symptoms but has associated adverse events. One RCT reported that non-cooling TUMT and TURP yield similar improvements in symptoms and physiological measures, and each has different adverse events.
- One retrospective study reported that fixed stents provide more symptom relief and greater improvements in peak urinary flow rates than spiral stents, TUT or TRH.
- Transrectal hyperthermia, transurethral thermotherapy, balloon dilation, and TULIP are outdated technologies not currently recommended by any professional organization.
- Ethanol ablations, photoselective vaporization of the prostate and water-induced thermotherapy are emerging therapies not yet studied in controlled trials.

The purpose of newer treatments for BPH is to approximate the efficacy of TURP and the other standard surgeries while decreasing the potential harms associated with the standard surgeries. Some of the less invasive treatments do appear to have fewer and/or less severe immediate complications and side effects, and symptom relief approaches that of TURP. Retreatment rates suggest that symptom relief may not be as long lasting as with TURP. However, the published controlled trials are mostly small and short-term, and few of them completely reported the retreatment rates (particularly the need for TURP), adverse events and harms. Long-term effects of these treatments are currently unknown. Hence, it is presently difficult to definitively determine their place within the armamentarium of BPH treatments.