# FDA Cleared or Approved Indications for Devices Used in BPH Treatments

The following information was retrieved by ECRI’s database search staff, by querying FDA’s PMA and 510k databases online at http://www.fda.gov/cdrh/. The information provided reflects all available information specific to BPH that was available through FDA. Note that many devices, particularly lasers, are FDA cleared for general indications, rather than for BPH specifically. If the cleared indications for a particular device did not mention BPH specifically, or was approved as a predicated device by the 510(k) process, we did not include information about that device in this table.

Table F- 1 FDA Regulation Status For BPH Treatment Devices

Treatment | Device (Manufacturer) | FDA approved/cleared urological indications | FDA approved/cleared contraindications
Laser procedures | CL MD Laser Systems (SLT) | CLAP – prostates up to 45 grams VLAP – prostates up to 75 grams | No details available
| Right Angle and Optilase Lasers (Trimedyne) | For coagulation of soft tissue for prostatectomy in the treatment of BPH (no further details available) | No details available
| Medilas D Laser family (Dornier Medtech) | >Age 50 Median and/or lateral lobes ranging from 28–85 cc | No details available
| Indigo® OPTIMA Laser System (Ethicon Endo-Surgery, Inc.) | Symptoms of BPH (Nothing more specific) | No details available
RFNA (TUNA®) | TUNA® (Medtronic) | Age >50 years Prostate size 20–50 cc Symptoms due to urinary flow obstruction secondary to BPH | Active UTI Neurogenic bladder Severe urethral stricture Bleeding disorders or patients taking anticoagulation medication unless antiplatelet meds have been discontinued for at least 10 days ASA Class group V patients Prostatic or bladder cancer Prostate gland <34 mm or >80 mm in transverse diameter Prosthetic device that may interfere with procedure Prostates previously treated with non-pharmacological therapies Presence of cardiac pacemaker, implantable defibrillator, or malleable penile implants Presence of implantable neurostimulation system.
HIFU | Sonablate® 500 System (Focus Surgery Inc.) | Not yet cleared by FDA | Not yet cleared by FDA
TUMT | Prostatron (Urologix) | Prostatron 2.0 (60 W max): Prostatic length of 35–50 mm Prostatron 2.5 (70 W max): Prostatic length of 25–50 mm Benefits of obstructive improvement outweigh the attendant risks | Peripheral artery disease with intermittent claudication Leriches syndrome Prostate or bladder cancer Severe urethral stricture Cardiac pacemaker, implantable defibrillator, or metallic implant in hip, pelvis, or femur.
| Targis (Urologix) | Prostatic length of 30–50 mm Prostatic urethra length of 25–35 mm | Prior pelvic radiation (Other contraindications do exist but full product labeling information was not available.)
TUMT | CoreTherm (Prostalund) | Prostate size of 30–100 g and length ≥35 mm | Severe urethral stricture Penile or urinary sphincter implants Previous radiation of pelvic region Bladder cancer Active prostatitis Active UTI Previous prostate or rectal surgery Wish to preserve fertility Implanted defibrillators, pacemakers, or other active implant Metallic implant in prostate treatment area Peripheral artery disease with inter
| TMX 2000 (Thermatrx) | Prostatic urethra length ≥30 mm Total prostate volume 30–100 cc Patients with bladder or prostate cancer CAN receive this treatment. | No details available.
| Prolieve™ System (Celsion) | Prostate size 20–80 grams Prostatic urethra length 1.2 cm – 5.5 cm Patients in whom drug therapy is typically indicated. | Patients whose pain has been relieved by any other treatment Severe urethral stricture Current urinary or prostatic infection Penile or urinary sphincter implant Peripheral artery disease with intermittent claudication Protruding middle lobe resulting in obstruction Evidence of prostate or bladder cancer Presence of metallic implants in pelvic region Presence of implanted cardiac pacemakers or defibrillators Previous transurethral prostatectomy Interest in preservation of fertility History of pelvic radiation Coagulation disorder Renal impairment Neurologic disorders affecting bladder function Bladder stones
Prostatic Stents | Urolume™ Endourethral Wallstent^R^ Prosthesis (American Medical Systems, Inc.) | To relieve prostatic obstruction secondary to benign prostatic hypertrophy (BPH) in men at least 60 years of age, or men under 60 years of age who are poor surgical candidates, and whose prostates are at least 2.5 cm in length | Fracture distraction defects of the posterior urethra; the device is not intended for temporary use
Water Induced Thermotherapy | Thermoflex™ WIT System (Argomed, Inc.) | >50 years old Symptoms of urinary obstruction Prostatic length 2.0–6.4 cm | No details available