# Treatment Acronyms and Abbreviations in Text and Evidence Tables

Table E- 1 Description of acronyms and short phrases to denote treatments

Short phrase | Description
Balloon | Balloon dilation
CLAP | Contact laser ablation of the prostate
Cystoscopy | Insertion of endoscope, as control for balloon dilation
Expanding stent | Stent that expands once inserted
Fixed stent | Stent that does not expand once inserted
HIFU | High intensity focused ultrasound
HoLAP | Holmium laser ablation of the prostate
HoLRP | Holmium laser resection of the prostate
HoLEP | Holmium laser enucleation of the prostate
Hybrid laser | Hybrid laser technique
ILC | Interstitial laser coagulation
ILC with stent | Interstitial laser coagulation with stent
Medication | Treatment with medication only
No treatment | No treatment intervention or conservative management
Open prostX | Open prostatectomy
Sham | Imitation surgical procedure in which no prostate tissue is removed
Spiral stent | Spiral stent
Stent biodeg. | Temporary biodegradable stent
Temporary catheter | Temporary catheter, as control for temporary biodegradable stent
TRH 3–5x | Transrectal hyperthermia 3–5 applications
TRH 3–5x + meds | Transrectal hyperthermia 3–5 applications, with medication
TRH 6–10x | Transrectal hyperthermia 6–10 applications
TRH 6–10x + meds | Transrectal hyperthermia 6–10 applications, with medication
TRH 6–10x no cath. | Transrectal hyperthermia 6–10 applications, no catheterization
TUCT | Temporary urethral catheter (a form of sham treatment)
TUEVP | Transurethral electrovaporization of the prostate
TUIP | Transurethral incision of the prostate
TULIP | Transurethral ultrasound-guided laser incision of the prostate
TUMT | Transurethral microwave thermotherapy
TUMT 3 sessions | Transurethral microwave thermotherapy, 3 sessions
TUMT 30 min. | Transurethral microwave thermotherapy for 30 minutes
TUMT 6 sessions | Transurethral microwave thermotherapy, 6 sessions
TUMT high dose apex | Transurethral microwave thermotherapy, high dose, focused on the apex of the prostate
TUMT high dose base | Transurethral microwave thermotherapy, high dose, focused on the base of the prostate
TUMT low dose apex | Transurethral microwave thermotherapy, low dose, focused on the apex of the prostate
TUNA | Transurethral needle ablation of the prostate
TUR syndrome | Transurethral resection syndrome
TURP | Transurethral resection of the prostate
TUT | Transurethral thermotherapy
VLAP | Visual laser ablation of the prostate
VLAP 1 catheter | Visual laser ablation of the prostate with one indwelling catheter
VLAP 2 catheters | Visual laser ablation of the prostate with indwelling and suprapubic catheters
VLAP DB | Visual laser ablation of the prostate with debridement
VLAP high power | Visual laser ablation of the prostate, high power
VLAP KTP | Visual laser ablation of the prostate using KTP fiber
VLAP low power | Visual laser ablation of the prostate, low power
VLAP painting | Visual laser ablation of the prostate, painting technique
VLAP with stent | Visual laser ablation of the prostate with stent
WIT | Water-induced thermotherapy

Table E- 2 Abbreviations in Evidence Tables

Table type | Abbreviations
Study Details | N – No NC – Not calculable NR – Not reported Y – Yes Reported Outcomes: S – Symptoms T –Technical measures A – Adverse effects R – Retreatment Q – Quality of life P or Peri – Perioperative N enrolled – The number of patients enrolled in the two groups for this treatment comparison
Patient Inclusion Criteria | cc – cubic centimeters E – Patients were excluded for this characteristic g – grams I – Patients were included even if they had this characteristic IPSS – International Prostate Symptom Score (AUA) NR – Not reported PSA – Prostate specific antigen PVR (mL) – Postvoid Residual Volume in milliliters Qmax (mL/sec) – Maximum urinary flow rate in milliliters per second umol/L – Micromoles per liter UTI – Urinary tract infection
Treatment Details | Ch – Charr (equivalent to French) F or Fr – French (gauge measurement) KTP – Potassium titanyl phosphate yttrium-aluminum-garnet fiber MHz – Megahertz N – Number Nd:YAG – Neodymium:yttrium-aluminum-garnet fiber NR – Not reported tid – Three times daily W – Watt
Patient characteristics | I BO – Barosky irritative score Md – Median Mn – Mean N – Number of patients NR – Not reported O BO – Barosky obstructive score PSA – Prostate specific antigen PVR – Post-void residual volume SD – Standard deviation SE – Standard error of the mean
Results and Change Comparisons | %chg – Percentage change from baseline %ile – Percentile 95% CI – 95% confidence interval Diff – Difference from baseline ICS – International Continence Society questionnaire IQR – Interquartile range md – Median mn – Mean N – Number of patients NR – Not reported NS – Not significant num pts – Number of patients Peri or P – Perioperative Post-op – Postoperative Q – Flow rate (quotient of volume/time) Ratio – Ratio of postoperative measure to baseline Rg – Range SD – Standard deviation SE – Standard error SEM – Standard error of the mean Sig. – Statistically significant SIR – Siroky maximum flow nomogram, expressed in standard deviation (SD) units.