# Excluded Studies

Table D- 1 Excluded studies and reasons for exclusion

Study | Reason for exclusion
Schelin (2002)(249) | Evaluated the use of intraprostatic and periprostatic injections of mepivacaine epinephrine during TUMT; thus, did not evaluate TUMT itself
Isotalo (2001)(250) | All patients received a spiral stent and after two weeks were randomized to receive either finasteride or placebo. Thus, this was a comparison of finasteride, which is beyond the scope of this review.
Petas (2000)(195) | Both treatment groups received ILC, but one received a biodegradable stent after treatment. This study evaluates the post-treatment usefulness of a biodegradable stent rather than ILC or stenting as a treatment itself.
Wada (2000)(251) | Assigned patients to treatments based on prostate size, thus treatment groups were not comparable.
Djavan (1999b)(252) | Although this study evaluates two treatment groups receiving TUMT, the real comparison is between patients who received adjuvant alpha-blockade versus those who did not during their TUMT treatment.
Lukkarinen (1999)(253) | All patients received balloon dilation and were randomized into those who received finasteride or placebo. Thus, this was a comparison of finasteride, which is beyond the scope of this review.
Shalev (1999)(254) | This was a nonrandomized, retrospective comparison of acute myocardial infarction rates after TURP and open prostatectomy. The patients were assigned treatment on the basis of prostate size, and so were not matched.
Eliasson (1998)(255) | This was a comparison of results for helical coil TUMT versus filament TUMT. The results were stratified according to response, rather than according to treatment.
Devonec & Dahlstrand (1998)(256) | Both treatment groups received TUMT, but one received a temporary stent after TUMT. Evaluated temporary stenting after TUMT rather than TUMT itself.
Grundy (1997)(42) | All patients got TUEVP, but they were randomized to receive either sterile water or glycine as irrigation fluid. Thus, this was a comparison of irrigation fluids rather than different BPH treatments.
Horninger (1997)(257) | Study assigned patients to treatments based on general health or prostate volume. Thus, the comparison groups were not comparable.
Bdesha (1996)(258) | This was a comparison of TURP vs. open prostatectomy. Patients in one group had previously received TUMT, whereas patients in the other group had not. Thus, they were not comparable.
De Wildt (1996)(259) | This study combined the results of Francisca et al. (1997)(171) and Ogden et al. (1993)(166) with longer followup time. However, there was an attrition rate of almost 50% after 3 months as patients were unblinded and given new treatment options. Thus, followup included only patients with successful treatment who did not seek additional treatment, which significantly biases results.
Te Slaa (1996)(260) | Study compared patients who received antibiotic prophylaxis for urinary tract infections (prior to BPH treatment) to patients who did not receive antibiotic prophylaxis. Therefore, it did not involve a comparison of treatments for BPH.
Abbou (1994)(258) | Results from patients receiving rectal hyperthermia and patients receiving urethral hyperthermia were combined.
Montorsi (1992)(187) | Transrectal hyperthermia. Treatment groups divided by age and thus not readily comparable.
Andersen (1990)(261) | This was a retrospective, nonrandomized comparison of mortality after TURP and open prostatectomy. The patients in the two groups were not matched and had different characteristics and disease severity.
Roos (1989)(262) | This was a retrospective, nonrandomized comparison of mortality and reoperation after TURP and open prostatectomy. The patients in the two groups were not matched and had different characteristics and disease severity.
Edwards (1982)(263) | This nonrandomized comparison of TUIP to TURP assigned treatment on the basis of prostate size, therefore the groups were not comparable.