# Literature Search Strategies

## Electronic Database Searches

We searched the following databases for relevant information:

Cochrane Database of Systematic Reviews (through 2003, Issue 2)

Cochrane Registry of Clinical Trials (through 2003, Issue 2)

Cochrane Review Methodology Database (through 2003, Issue 2)

Database of Reviews of Effectiveness (Cochrane Library) (through 2003, Issue 2)

ECRI Health Technology Trends (through December 2002)

ECRI International Health Technology Assessment (IHTA) (1991 through January 2003)

ECRI Library Catalog (through January 2003)

ECRI TARGET (through January 2003)

Embase (Excerpta Medica) (1991 through December 26, 2002)

PsycINFO (1989 through December 26, 2002)

PubMed (MEDLINE, PreMEDLINE, HealthSTAR) (1975 through November 14, 2003)

TRIP Database (through December 5, 2002)

U.K. National Health Service Economic Evaluation Database (NHS EED) (through January 2003)

U.K. National Institute for Clinical Excellence (NICE) (through December 17, 2002)

U.S. National Guideline Clearinghouse™ (NGC™) (through January 2003)

## PubMed searches

For PubMed, the following strategy was used to limit results to controlled clinical trials:

[underlined: Controlled clinical trials]:

(randomized controlled trials(164) OR random allocation(164) OR randomized controlled trial(8) OR double-blind method(164) OR single-blind method(164) OR “single-dummy” OR “double-dummy” OR controlled clinical trials(164) OR controlled clinical trial(8) OR placebo* OR controls[ab] OR “latin square”[tw])

All searches were limited to English language publications and human population.

The following strategy was used for these limits:

English[la] AND (human(164) OR premedline(222) OR publisher(222))

Benign Prostatic Hyperplasia (BPH):

1. prostatic hyperplasia(164)
2. “bph” OR “benign prostatic hyperplasia”
3. (benign OR enlarg* OR hyperplasia OR hypertroph*) AND prostat*
4. “bladder outlet obstruction” AND (male(164) OR prostate OR prostatic)
5. #1 OR #2 OR #3 OR #4
6. #5 NOT (adenoma* OR adenocarcinoma* OR neoplasms(164))
7. #5 NOT #6
8. #7 AND #2
9. #6 OR #8

Therapies for BPH:

Alcohol ablation of the prostate:

1. #9 AND (injections, intralesional(164) OR “chemo-ablation” OR chemoablation)
2. #9 AND (ethanol OR alcohol) AND (inject OR injection)
3. #9 AND sclerotherapy
4. #1 OR #2 OR #3

Balloon dilatation of the prostate (BDP):

1. #9 AND (balloon dilatation(164) OR (balloon AND dilat*) OR “BDP”)

Cryotherapy:

1. #9 AND (cryotherapy OR cryotherapeutic OR cryosurgery OR cryosurgical OR hypotherm*)

High-intensity focused ultrasound (HIFU):

1. #9 AND (ultrasonic therapy OR ultrasound OR ultrasonic) AND (transrectal OR rectal OR endorectal)
2. #9 AND (“high-intensity focus ultrasound” OR “HIFU”)
3. #9 AND sonoblate
4. #1 OR #2 OR #3
5. #4 AND (therapeutic use[sh] OR therapy[sh] OR publisher(222) OR premedline(222))

Laser surgery:

1. #9 AND (laser surgery(164) OR (laser AND (ablation OR interstitial OR holmium OR Endoscopic)) OR ELAP OR VLAP OR HoLEP OR HOLEP)

Open prostatectomy:

1. #9 AND prostatectomy AND (open OR invasive)

Prostatic stents:

1. #9 AND (stent* OR stents OR endoprosthes*)

Transurethral incision of the prostate (TUIP):

1. #9 AND (“Transurethral incision” OR “TUIP”)

Transurethral microwave therapy (TUMT) of the prostate:

1. #9 AND (microwaves(164) OR microwave* OR “TUMT”)

Transurethral needle ablation (TUNA) of the prostate:

1. #9 AND (“Transurethral needle ablation” OR (needle AND ablat*) OR radiofrequency OR “radio-frequency” OR “radio frequency” OR “RF” OR “TUNA”)

Transurethral resection of the prostate (TURP):

1. #9 AND (“Transurethral resection” OR “TURP”)

Transurethral vaporization of the prostate (TUVP):

1. #9 AND (electrovaporization OR “TUVP” OR vaporization OR “vapor-cut” OR rotoresection OR “TUVRP” OR rotoresect* OR gyrus OR wing)
2. #9 AND (electrocoagulation OR electrosurgery OR electrosurgical OR electrocautery OR loop)
3. #9 AND (“Transurethral evaporation” OR “TUEP”)
4. #1 OR #2 OR #3

Watchful-waiting:

1. #9 AND (“watchful-waiting” OR “watchful waiting”)
2. #9 AND (“untreated”[ab] OR “non-treatment”)
3. #1 OR #2

Water-induced thermotherapy (WIT):

1. #9 AND (water[tw] OR water(164)) AND (Hyperthermia, induced(164) OR thermotherapy OR thermal*)
2. #9 AND thermoablation
3. #9 AND (“water-induced” OR “WIT”)
4. #9 AND thermoflex
5. #9 AND (“hot-water” OR (hot AND water))
6. #2 OR #3 OR #4 OR #5

## EMBASE searches

Below is the search strategy we used for EMBASE:

S1 | s prostat?(2n)(hyperplasia or hypertrophy)
S2 | s benign()prostatic()hyperplasia or bph
S3 | s s1 or s2
S4 | s s3 and py=1989:2003
S5 | s s4/eng
S6 | s s5/human
S7 | s s6 and (urinary()tract()obstruction or prostatectomy of intermethod()comparison or transurethral()resection or laser()surgery or Transurethral()needle()ablation)
S8 | s s6 and (TURP or TUIP or TUMT or TUNA or TUVP or TUEP or VLAP HIFU or WIT)
S9 | s s6 and (prostatectomy and Transurethral and resect?)
S10 | s s6 and (microwaves/de or microwave)
S11 | s s6 and (Transurethral()needle()ablation or (needle and ablat?) or radiofrequency or radio()frequency or rf)
S12 | s s6 and (prostatectomy and (open or invasive or traditional))
S13 | s s6 and (Transurethral and incision)
S14 | s s6 and (Transurethral()resection or turp or tur)
S15 | s s6 and (stent? Or stents/de)
S16 | s s6 and (balloon dilatation/de or (balloon and dilatation))
S17 | s s6 and (wit or water()induced or ((water/de or water) and (Hyperthermia, induced/de or thermoablation or thermotherapy or thermal?)))
S18 | s s6 and (hifu or high()intensity()focus()ultrasound)
S19 | s s6 and (laser surgery/de or (laser and (ablation or interstitial or holmium or Endoscopic)) or elap or vlap or holep or HoLEP)
S20 | s s6 and (electrocoagulation or vaporization or electrosurgery or evaporation or electrosurgical or electrocautery or loop or vapor()cut or tuvrp or gyrus or wing or electrovaporization)
S21 | s s6 and ((alcohol and ablat?) or chemoablat? Or sclerotherap? Or inject?))
S22 | s s7 or s8 or s9 or s10 or s11 or s12 or s13 or s14 or s15 or s16 or s17 or s18 or s19 or s20 or s21
S23 | s s22 and ((controlled study! Or clinical trial! Or randomization or cross-over procedure or double blind procedure or single blind procedure or placebo)/de or double()dummy or double()blind or single()blind or single()dummy)
S24 | s s22 and (sham or random? Or placebo?)
S25 | s s23 or s24
S26 | s s25 not (letter or comment or editorial or news or case()report or notes or conference()paper)