# Description of Utilities

This section focuses on patients’ reactions to the outcomes of BPH treatments (or morespecifically, “utilities”, described in detail below). We first provide background information on what utilities are and how they are measured. Then, we review the evidence on patients’ utilities for the outcomes of treatments for BPH.

## Background on utilities

The word “utility” in medical decision making refers to the relative amount of value or worth that a patient places on a given outcome.^7^ Utility is measured on a scale from 0 to 1 where 0 indicates the lowest possible utility and 1 indicates the highest possible utility. Suppose a patient is asked how he would feel if he had severe incontinence. If a patient places a relatively low utility (such as 0.25) on this health state, then this means that he perceives it quite negatively. Alternatively, if the patient assigns a relatively high utility to this health state (e.g., 0.85), then he does not think it would be so bad. Using utilities, a patient can express his opinions about the relative values of different outcomes. The concept of utility has been used in a medical decision analysis of BPH treatments to compare the overall desirability of different treatments.(239) Also, utilities have been employed in cost-effectiveness analyses^8^ of BPH treatments.(22,240–242)

7 The concept of utility was introduced by economists to explain why different people perceive the value of money differently. Researchers have applied utilities to medical decision analysis by computing an “expected utility” for each treatment, and the treatment with the highest expected utility is preferred. An introduction to this topic appears in a book by Sox, Blatt, Higgins, et al. (1988).(245) Utilities are also used as quality weights in quality-adjusted life years (“QALYs”) as a way to compare treatments for their combined effects on quality and quantity of life.(264)

8 A cost-effectiveness analysis that uses utilities to measure effectiveness is also referred to as a “cost-utility” analysis.

Utilities can be measured in several ways. Here, we describe two methods for measuring utilities: the time tradeoff (TTO) and the standard gamble (SG). The time tradeoff method (TTO) presents patients with a series of hypothetical choices. By asking the patient to state his preferences between hypothetical alternatives, the researcher can determine the degree of subjective value or worth that the patient places on an outcome. The central issue is how many years of life the patient is willing to give up in order to avoid living with a debilitating health state. If a patient perceives the health state as being extremely poor, then he may be willing to live a shorter life if it means he could avoid the debilitating health state. For example, to determine a patient’s TTO utility for severe incontinence, a researcher would first ask the patient to choose between the following two hypothetical alternatives:

[underlined: Alternative A]: You live for the next 10 years with severe incontinence, after which you would die painlessly.

[underlined: Alternative B]: You live for the next 9 years in perfect health (i.e., no symptoms of BPH), after which you would die painlessly.

Some patients may be willing to give up a year of life in order avoid severe incontinence, but other patients may not be willing. If the patient prefers Alternative A, then the researcher presents another hypothetical choice in which Alternative B is made more attractive by increasing the number of years in perfect health (e.g., to 9.5 years).^9^ The patient is then asked to choose between these new Alternatives A and B. The process continues until the patient is indifferent between the two alternatives (i.e., A and B are equally preferable). The point of indifference determines the patient’s utility. For example, suppose the patient is indifferent between Alternatives A and B when Alternative B is 8.5 years in perfect health. This would mean that the patient’s TTO utility for severe incontinence is 8.5/10 or 0.85.

9 If the patient prefers Alternative B, then Alternative B is made less attractive by decreasing the number of years in perfect health (e.g., to 8.5 years). The process continues until the patient is indifferent between the alternatives.

Like the TTO, the standard gamble method (SG) requires patients to make choices between hypothetical alternatives. Unlike the TTO, however, the SG uses the concept of risk. For example, suppose one wants to determine a patient’s SG utility for severe incontinence. To measure this utility, Ackerman, Rein, Blute, et al. (2000)(22) asked patients with BPH to choose between the following hypothetical alternatives:

[underlined: Alternative A]: Severe incontinence. You have undergone treatment for BPH that results in a total loss of voluntary control over urination.

[underlined: Alternative B]: A gamble in which there is a 90% chance of having perfect health (i.e., no BPH symptoms and no adverse events), but there is a 10% chance of death.

If the patient prefers Alternative A, then Alternative B is made more attractive by increasing the chance of perfect health (e.g., to 95%) and decreasing the chance of death (e.g., to 5%),^10^ and the patient is asked to choose between these new Alternatives A and B. As with the TTO, the process continues until the patient is indifferent between the two alternatives. The point of indifference determines the patient’s utility. For example, suppose the patient is indifferent between Alternatives A and B when Alternative B is a 95% chance of perfect health and a 5% chance of death. This would mean that the patient’s utility for severe incontinence is 95/100 or 0.95.

10 If the patient prefers Alternative B, then Alternative B is made less attractive by decreasing the chance of perfect health (e.g., to 85%) and increasing the chance of death (e.g., to 15%). The process continues until the patient is indifferent between the alternatives.

The two methods approach the problem differently, and they can produce different results.(243) The SG (but not the TTO) incorporates patient’s attitudes towards risk, and because patients tend to be averse to risks,(244) the SG is assumed to be as the “gold standard” for utility measurement.(245)

One difficulty with utility measurement concerns the hypothetical nature of the elicitation process. Both methods require the patient to imagine what it would be like to live in a specific health state. The patient’s responses are based, therefore, on his imagined response to this health state, which may be different from his true response to the health state if he actually experienced it. However, this difficulty is not unique to utility measurement. In any medical treatment, outcomes may occur that the patient has never experienced, and the patient’s reaction to those outcomes cannot be known in advance.

A more fundamental difficulty with utility measurement concerns the quantifiability of patient’s values. Both methods attempt to assign a number to a patient’s opinion about a health state. This number may depend on many unintended factors, such as the way the health state is described(246) or the manner in which the choice is framed.(247) Also, a patient’s opinion can change over time, suggesting that no single number can fully capture his beliefs about a health state.(248) With these caveats in mind, the next section reviews the available evidence on patients’ utilities for the outcomes of BPH treatments.

## Evidence on utilities for BPH

Only two studies have reported BPH patients’ utilities (in their technical sense) for treatment outcomes.^11^ Ackerman et al. (2000)(22) used the standard gamble to measure the preferences of 13 men with moderate to severe symptoms of BPH.^12^ They reported the mean SG utilities for five short-term events and 17 long-term outcomes of BPH treatments. According to the mean SG utilities, patients perceive myocardial infarction as the worst among the five short-term events, followed by deep venous thrombosis. Among the long-term outcomes, patients perceived severe incontinence as the worst, followed by urinary retention. These utilities, which were 0.80 and 0.82, respectively, show that patients perceive these outcomes rather negatively. Also, note that there were three categories of remission: no remission, moderate remission, and significant remission. Within each of these categories, there was a consistent ordering of three adverse events: erectile dysfunction, urinary incontinence, and ejaculatory dysfunction. Specifically, the typical patient thought erectile dysfunction was worse than urinary incontinence, which was perceived to be worse than ejaculatory dysfunction.

11 Two additional studies addressed similar issues, but they are not discussed here for the following reasons. Krumins, Fihn and Kent (1988)(265) employed the time tradeoff (TTO) technique to measure the utilities of men with BPH, but they did not report summary statistics on the measured TTO utilities. Llewellyn-Thomas et al. (1996)(266) reported SG utilities of a group of men who were seen at a urology clinic for an initial diagnostic assessment for BPH, and some of them may not have had BPH.

12 As measured by I-PSS symptom scores between 15 and 29, inclusive.

Schulz et al. (2002)(23) used the time tradeoff (TTO) technique to measure utilities. They enrolled 29 patients with a mean I-PSS symptom score of 16.2, indicating that the typical patient had moderate LUTS. Each patient performed the time tradeoff task for each of two health states (current level of symptoms, and the worst possible level of symptoms) at each of two time intervals (1 year and 10 years). The mean TTO utilities (and ranges) appear in Table B- 2. The typical patient was willing to give up 14%–20% of time in order to relieve their current symptoms. When presented with a hypothetical situation involving the worst possible BPH symptoms,^13^ the typical patient was willing to give up 46%–52% of time in order to avoid that scenario.

13 As defined by an I-PSS score of 35, which is the maximum on this instrument.

In summary, one study used the standard gamble method, whereas the other used the time tradeoff method. The study by Ackerman et al. (2000)(22) showed that the typical patient was willing to risk death in order to avoid potential short term adverse events (such as myocardial infarction) and long-term outcomes (such as severe incontinence). The study by Schulz et al. (2002](23) found that the typical patient was willing to give up some of their lifespan in order to cure their current symptoms of BPH. Jointly, the studies indicate a clear desire on the part of patients both to cure their symptoms and to avoid adverse events. However, because there were only two studies, the findings prevent firm conclusions about patients’ precise values.

Table B- 1 Mean standard gamble utilities in Ackerman et al. (2000)

Short-term events | Mean SG utility^1^ | Range
Myocardial infarction | 0.78 | 0.69 – 0.95
Deep venous thrombosis | 0.89 | 0.74 – 0.99
Severe urinary tract infection | 0.93 | 0.77 – 0.99
Urethral stricture/bladder neck contracture | 0.94 | 0.78 – 1
Dysuria | 0.97 | 0.83 – 1
Long-term outcomes^2^ | Mean SG utility | Range
Severe incontinence | 0.8 | 0.5 – 0.98
Urinary retention | 0.82 | 0.5 – 1
Worsening BPH and ejaculatory dysfunction | 0.9 | 0.78 – 1
Worsening BPH and no adverse events | 0.92 | 0.78 – 1
No remission and erectile dysfunction | 0.9 | 0.78 – 1
No remission and urinary incontinence | 0.93 | 0.82 – 1
No remission and ejaculatory dysfunction | 0.95 | 0.78 – 1
No remission and no adverse events | 0.96 | 0.83 – 1
Moderate remission and erectile dysfunction | 0.92 | 0.83 – 1
Moderate remission and urinary incontinence | 0.94 | 0.82 – 1
Moderate remission and ejaculatory dysfunction | 0.96 | 0.84 – 1
Moderate remission and no adverse events | 0.98 | 0.92 – 1
Significant remission and erectile dysfunction | 0.93 | 0.83 – 1
Significant remission and urinary incontinence | 0.95 | 0.84 – 1
Significant remission and ejaculatory dysfunction | 0.97 | 0.84 – 1
Significant remission and no adverse events | 1 | 0.94 – 1

1 These means were calculated by ECRI based on the means provided in Table I on page 975 of Ackerman, Rein, Blute, et al. (2000).(22) Values were rounded to the nearest 0.01.

2 An additional long-term outcome was “moderate-to-severe BPH,” which was identical to the outcome “No remission and no adverse events”, thus it is not listed separately in the table. This outcome corresponds to no effect of the treatment (i.e., no benefit and no harm). The authors also reported utilities for three treatments for BPH, but these are not listed in the table because this section addresses the utilities for potential outcomes of treatments, not utilities for the treatments per se.

SG - Standard gamble utility (see explanation in text).

Table B- 2 Mean time tradeoff utilities in Schulz et al. (2002)

Health state | Time interval^1^ | Mean TTO utility | Range
Current level of symptoms | 1 | 0.86 | 0.13–1
Current level of symptoms | 10 | 0.80 | 0.05–1
Worst possible level of symptoms^2^ | 1 | 0.54 | 0.04–1
Worst possible level of symptoms^2^ | 10 | 0.48 | 0.05–1

1 The time interval refers to the time that the patient would spend in the corresponding health state. For example, in the first row, the typical patient was indifferent between living for 1 year with current symptoms and living for 0.86 years in perfect health. The second row indicates that the typical patient was indifferent between living for 10 years with current symptoms and living for 8 years (0.80 × 10) in perfect health.

2 The worst possible level of symptoms was defined as an I-PSS score of 35, which is the highest (worst)possible score on that instrument.

TTO Time tradeoff (see explanation in text).