# Description of Outcome Measures

Trials of treatments for benign prostatic hyperplasia (BPH) examine the effects of treatment on several outcomes. These outcomes may be either beneficial or harmful. Below, we first discuss outcomes that measure potential benefits, and subsequently we describe several potential harms.

## Potential Benefits

There are three categories of benefits of treatments for BPH: symptoms, physiological measures, and quality of life. Symptoms and quality of life (QoL) are subjective, patient-oriented measures obtained using questionnaires completed by patients, whereas physiological measures are objective measures determined by physicians using systematic instrumented measurements of the functioning of the lower urinary tract. These categories are further defined and described below.

The literature on BPH distinguishes between measurements of a patient’s symptoms, and the degree to which the patient is bothered by those symptoms. This is because two patients can have the same level of symptoms, and one patient may be greatly bothered while the other is relatively unbothered. We discuss degree of bother in the section on quality of life.

### Symptoms

Men with BPH experience many symptoms due to enlargement of the prostate. These include a high frequency of urination, pushing or straining during urination, or a painful or burning sensation during urination. To measure symptom severity, clinical trials often use a questionnaire that is completed by the patient. Using a standardized questionnaire ensures that different patients are asked precisely the same questions about their symptoms. Further, if different trials use the same questionnaire, then one can compare the degree of symptom improvement across trials. The most commonly used questionnaire is the International Prostate Symptom Score (IPSS)^5^, which appears in Table A- 1.(20) It contains seven questions related to prostate symptoms, and the scores for each question are added to yield a single summary score. The summary score ranges from zero (indicating no symptoms) to 35 (indicating very severe symptoms). A score of seven or less indicates mild symptoms, a score between eight and 19 indicates moderate symptoms, and a score of 20 or higher indicates severe symptoms.(20) Although these cutoff points are arbitrary, a recent review article suggested that this categorization can be used to identify patients with mild symptoms who generally do not require treatment, or to identify patients with severe symptoms for whom treatment is more urgent.(197) The IPSS requires only a sixth-grade reading level,(198) it has been translated into many languages,(197) and it has been recommended for use by the International Consultation on BPH.(199) An estimated 99% of urologists are aware of the IPSS, and 63% use it in clinical practice.(199)

5 The IPSS is also known as the American Urologist Association Symptom Score (AUA).

In addition to the IPSS, several other BPH symptom questionnaires have been developed (Table A- 2). All of these questionnaires contain questions similar to those in the IPSS (e.g., nighttime frequency of urination, weak urinary flow, incomplete emptying of the bladder). Some pose questions not in the IPSS, such as questions about hesitancy before urination and post-urinary dribbling. All of the questionnaires employ slightly different wording and use different response scales that could potentially influence patients’ scores. However, the correlations between questionnaires are all high (published correlations range from 0.51 to 0.93),(200,201) indicating that they measure similar aspects of patients’ BPH symptoms.(200)

All of the symptom questionnaires rely on patients’ memories of their recent symptoms. Because memories are imperfect, it is important to assess both the validity and reliability of symptom questionnaires. Validity refers to whether a questionnaire measures what it is intended to measure. In the present context, there is no “gold standard” for the patient’s true symptoms, so one cannot assess validity in the strictest sense. Consequently, researchers have attempted to assess validity indirectly (specifically, “construct” validity) by determining whether patients’ scores on a symptom questionnaire correlate well with other relevant measures, such as whether patients report global improvement after treatment. If they do, then the questionnaire is said to have construct validity. This has been established for three of the questionnaires listed in Table A- 2. The IPSS correlates well with the degree to which patients were bothered by their symptoms,(20) patient global ratings of improvement after treatment,(202) and global ratings of bother.(20) The Dan-PSS(203) and the ICSmaleSF(204) also correlate well with these measures.

Reliability refers to the repeatability of a questionnaire. Two types of reliability are usually investigated: test/retest reliability and internal consistency. Test-retest reliability concerns whether the same patient gives the same answers at different times. For example, a patient could complete a symptom questionnaire on March 1^st^, and then complete it again on April 1^st^. If the patient gives the same responses, then the test has good test-retest reliability (assuming there was no treatment intervention during the month of March). Internal consistency addresses whether responses to individual questions in the questionnaire are correlated, and if so, they are believed to measure the same underlying construct. Empirical trials have found good test-retest reliability (Pearson r 0.8–0.9) and good internal consistency reliability (Cronbach’s alpha 0.7–0.8) for three symptom questionnaires (the same three for which validity has been established): the IPSS,(20) the Dan-PSS,(203) and the ICSmaleSF.(204)

Despite the fact that these questionnaires are reliable and valid, there are challenges to using them to measure the effect of treatment. This is because patients generally expect to improve after treatment. Thus, they may report fewer symptoms after treatment even if there was no real improvement.(24) This possibility is strong motivation for the use of a blinded control group in any trial of BPH treatment. Patients in both groups (the treatment group and the control group) might expect to improve, thus any comparison between groups must factor out any effect of patients’ expectations.

Ideally, patients in the control group would receive a placebo, because the placebo effect is a well-established finding in BPH research. In a review of 1,417 patients in 45 placebo arms of BPH clinical trials, Roehrborn (1996)(205) found that 42% of placebo-treated patients experienced an improvement in their symptoms after “treatment.” In addition, the review noted that the Food and Drug Administration and the World Health Organization “advocate rather strictly the use of placebo controls” (p 242) in the field of BPH research.(205)

Expectation is less likely to affect more objective outcome measures, such as the physiological measures described in the next section. However, as discussed below, these physiological measures are an indirect way to measure the most important outcomes of treatments for BPH.

Table A- 1 International Prostate Symptom Score (IPSS)

Question | Not at All | Less Than 1 Time in 5 | Less Than Half the Time | About Half the Time | More Than Half the Time | Almost Always
Over the past month, how often have you had a sensation of not emptying your bladder completely after you finish urinating? | 0 | 1 | 2 | 3 | 4 | 5
Over the past month, how often have you had to urinate again less than two hours after you finished urinating? | 0 | 1 | 2 | 3 | 4 | 5
Over the past month, how often have you found you stopped and started again several times when you urinated? | 0 | 1 | 2 | 3 | 4 | 5
Over the last month, how difficult have you found it to postpone urination? | 0 | 1 | 2 | 3 | 4 | 5
Over the past month, how often have you had a weak urinary stream? | 0 | 1 | 2 | 3 | 4 | 5
Over the past month, how often have you had to push or strain to begin urination? | 0 | 1 | 2 | 3 | 4 | 5
Quality of life question (IPSS QOL)
| None | 1 Time | 2 Times | 3 Times | 4 Times | 5 + Times
Over the past month, how many times did you most typically get up to urinate from the time you went to bed until the time you got up in the morning? | 0 | 1 | 2 | 3 | 4 | 5

The scores for each question are added to yield the summary symptom score, which ranges from 0 (indicating no symptoms) to 35 (indicating very severe symptoms).(20)

Table A- 2 Symptom Questionnaires

Questionnaire | Primary reference | Number of questions | Validity? | Reliability?
Boyarsky^a^ | Boyarsky et al. (1977)(206) | 9
Madsen and Iversen | Madsen and Iversen (1983)(21) | 9
IPSS (AUA) b | Barry et al. (1992)(20) | 7 | ✓ | ✓
Dan-PSS | Hansen et al. (1995)(203) | 12 | ✓ | ✓
ICSmaleSF | Donovan et al. (2000)(207) | 11 | ✓ | ✓

IPSS - International Prostate Symptom Score (also called the American Urologist Association Symptom Score)

Dan-PSS - Danish Prostatic Symptom Score

ICSmaleSF - International Continence Society Symptom Frequency for males

a Bolognese(208) proposed a slight alteration of the Boyarsky scale, thus it is not listed in the table

b The Maine Medical Assessment Program questionnaire(209) was an early version of the IPSS, thus it is not listed in the table

✓ Indicates that reliability or validity have been tested and confirmed (see explanation in text)

### Physiological measures

BPH involves an enlargement of the prostate that decreases bladder capacity and restricts the flow of urine. Thus, physiological measures such as prostate size, speed of urine flow, and pressure on the urethra are reported in trials of treatments for BPH. The commonly reported physiological measures are listed and described in Table A-3.

Physiological measures are relevant because they are objective measures of physiological causes of the symptoms of BPH. If these measures really do reflect the causes of the symptoms, then one would expect high correlations between physiological measures and symptom scores. Several trials have investigated such correlations, and all have concluded that they are low.(210–213) For example, a 1995 trial by Bosch, Hop, Kirkels et al.(212) found only a small correlation (Spearman r = 0.19) between symptom scores on the IPSS and prostate volume (a list of the published correlations appears in Table A-4). This suggests that, on average, there is a slight tendency for men with more symptoms to have larger prostates. However, it also suggests that there were some men with mild symptoms and large prostates, and there were other men with severe symptoms but small prostates. Consequently, prostate size itself does not adequately explain why some men have mild symptoms and others have severe symptoms.

Given the absence of strong correlations between symptoms and physiological measures, which outcome category is more important in assessing the efficacy of treatments for BPH? Symptom scores are more patient-oriented: a patient cares more about his symptoms than the actual speed of urinary flow or the size of his prostate. The physiological measures, therefore, are indirect measures of what matters to patients.

Thus, in the face of a discrepancy between symptom scores and physiological measures, a patient-oriented analysis would emphasize the symptom scores. However, symptom scores are vulnerable to expectation effects, whereas physiological measures are relatively free from such effects. Expectation effects on symptom scores motivate the need for blinded control groups in BPH treatment trials, because the expectation effects would be cancelled out in any between-groups comparison.

Although physiological measures are less susceptible to placebo effects than are symptom scores, they are still susceptible to a statistical artifact called regression to the mean.(24) Symptoms of BPH fluctuate over time,(214,215) and patients tend to be recruited into trials when they are relatively sick (i.e., when they meet stringent inclusion criteria).(24) An observed “improvement”, therefore, may simply reflect a return to the patient’s typical level of health.^6^ For example, a patient could be recruited into a trial when he had a relatively slow urinary flow rate (a physiological measure). During the trial, the patient’s flow rate could be faster, not because of the treatment, but instead because the trial observed a more typical flow rate for that patient (i.e., closer to that patient’s mean). Regression to the mean provides further motivation for the use of a control group in any clinical trial of BPH. Patients in different groups but the same selection criteria would likely experience the same amount of regression to the mean, so the between-groups comparison would not be confounded.

6 The “improvement” could also be due to a placebo effect. Both of these possibilities (regression-to-the-mean and a placebo effect) are contrary to the claim that the improvement was actually caused by the treatment. For a detailed discussion of this point, see Sech, Montoya, Bernier et al. (1998).(24)

Table A- 3 Physiological measures

Measure (abbreviation) | Description
Peak urinary flow rate (Q_max_) | During urination, the maximum amount of urine expelled per minute (measured in liters per minute or milliliters per minute). Higher values indicate better outcomes.
Voided volume | The amount of urine expelled during urination (measured in liters or milliliters). Higher values indicate better outcomes.
Postvoid Residual Volume (PVR) | After urination, the amount of urine remaining in the bladder (measured in liters or milliliters). Lower values indicate better outcomes.
Relative Residual Volume | The percentage of urine remaining in the bladder after urination. Lower values indicate better outcomes.
Prostate volume | Size of the prostate (measured in cubic centimeters). Lower values indicate better outcomes.
Detrusor pressure at peak urinary flow | During urination, the amount of pressure on the urethra (measured in number of centimeters water) at the time of peak urinary flow. Lower values indicate better outcomes.
Urethral resistance factor | During urination, the amount of pressure on the urethra (measured in number of centimeters water) at zero flow rate, interpolated from a plot of flow rate and pressure. See Bosch(216) for details. Lower values indicate better outcomes.
Minimal urethral opening pressure | During urination, the minimum amount of pressure on the urethra (measured in number of centimeters water) at the beginning of urination, interpolated from a plot of flow rate and pressure. See Bosch(216) for details. Lower values indicate better outcomes.
Prostate specific antigen (PSA) | An antigen in the blood that is released by the prostate (measured in nanograms per milliliter). Lower levels of this antigen indicate better outcomes.

Table A- 4 Correlations between physiological measures and symptom scores

Physiological measure | Correlation with symptom scores^a^
Maximum flow rate (Q_max_)^b^ | −0.07(210) −0.12(211) −0.18(212) −0.24(213)
Average flow rate | −0.13(210) −0.25(213)
Postvoid residual volume (PVR) | 0.01(210) 0.05(211) 0.25(212)
Relative residual volume | 0.10(211)
Voided volume | −0.21(213)
Total prostate volume^c^ | −0.09(210) 0.03(211) 0.19(212)
Central prostate volume^d^ | 0.24(212)
Prostate specific antigen (PSA) | −0.06(210)
Obstruction grade^e^ | 0.02(211)

a Symptom score as measured by the International Prostate Symptom Score (IPSS)

b Donovan, Abrams, Peters et al. (1996](204) also found a weak relation between maximum flow rate and symptom scores, but they did not report the value of the correlation.

c Simpson, Fisher, Lee et al. (1996](213) computed the correlation between total prostate volume and symptom scores, and found “no statistically significant relation”, but they did not report the value of the correlation.

d Volume of the central part of the prostate.

e Obstruction grade is an urodynamic parameter derived from the minimal urethral opening pressure.(211)

### Quality of life

Some trials report how treatments of BPH affect patients’ overall quality of life (QOL). This is a more general outcome measure than symptoms, physiological measures, or adverse events, because QOL can incorporate cognitive abilities, activities of daily living, and family relationships. With regard to BPH, QOL measures can assess the bothersomeness of a patient’s symptoms. Two patients can have identical symptoms, but one patient may be greatly bothered by those symptoms and the other patient relatively unbothered.

Quality of life questionnaires can be grouped into two categories: disease-specific and generic. Disease-specific questionnaires only contain questions about how BPH itself affects quality of life. For example, one disease-specific question is: “If you were to spend the rest of your life with your prostate symptoms just as they are now, how would you feel about that?”(20) Patients respond on a 0–6 scale where 0 means “delighted” and 6 means “terrible.” By contrast, a generic QOL questionnaire does not refer to any particular disease, but instead contains questions about the patients’ QOL in general.

For example, one question in the Short Form 36 (SF-36) asks: “During the past 4 weeks, how much did pain interfere with your normal work (including work both outside the home and housework)?”(217) Patients respond on a 0–4 scale where 0 means “not at all” and 4 means “extremely.” Disease-specific questionnaires are more sensitive than generic questionnaires to BPH treatment effects.(218–220)

A list of the QOL questionnaires that have been used to assess BPH treatments appears in Table A- 5. Some questionnaires consist of only one question,(20,207) whereas one contains 44 questions.(221) As with the symptom questionnaires discussed earlier, all of these questionnaires are vulnerable to expectation effects, and the use of blinded control groups can address this difficulty.

Table A- 5 Quality of life questionnaires

Disease-specific quality of life questionnaires
| Number of questions | Description
BPH Impact Index | 4 | Questions about the bothersomeness of specific BPH symptoms, including physical discomfort, worry, trouble with urination, and prevention of normal activities. Summary score ranges from 0 to 13 where 0 indicates no bother and 13 indicates extreme bother.(202)
Global question^a^ | 1 | “If you were to spend the rest of your life with your prostate symptoms just as they are now, how would you feel about that?” (0 = Delighted, 1 = Pleased, 2 = Mostly satisfied, 3 = Mixed, 4 = Mostly dissatisfied, 5 = Unhappy, 6 = Terrible)(20)
Bothersomeness questions in Dan-PSS | 12 | Questions about the bothersomeness of specific BPH symptoms. Each question corresponds to a symptom question in the Dan-PSS.(203) The summary score for bother ranges from 0 to 36 where 0 indicates no bother and 36 indicates extreme bother.
ICSQoL single question^b^ | 1 | “Overall, how much do your urinary symptoms interfere with your life?” (0 = not at all, 1 = a little, 2 = somewhat, 3 = a lot)(207)
ICSQoL | 6 | Questions about bothersomeness of symptoms and interference with daily life.(222)
QOL9 | 9 | Ratings from 0–10 for each of nine domains. Minimum score is 0, maximum score is 90.(223)
Epstein | 44 | Questions in each of six domains. Minimum score is 0, maximum score is 239.(221)
Generic quality of life questionnaires
Short Form-36 (SF-36) | 36 | Questions in each of eight domains: physical functioning, role limitations due to physical problems, social functioning, bodily pain, general mental health, role limitations due to emotional problems, vitality, and general health perceptions.(217,224–227)
EuroQOL | 14 | Questions in each of six domains: mobility, self-care, usual activities, pain/discomfort, mood, and general health.(228,229)
Psychological General Well Being | 22 | Questions in each of five domains: depression, anxiety, self-control, vitality, and positive attitude.(230,231)
Nottingham Health Profile | 38 | Questions in each of six domains: energy level, pain, emotional reaction, sleep, physical mobility, and social isolation.(228,232)
Functional Living Index - Cancer | 22 | Questions related to social support, activities of daily living and other domains.(233,234)
Rand Mental Health Index-17 | 17 | Questions in five domains of psychological distress and well-being: anxiety, depression, behavioral-emotional control, belonging/loneliness, and positive affect.(233,235)

a This is an optional add-on to the International Prostate Symptom Score (IPSS).

b This is an optional add-on to the International Continence Society Symptom Frequency for males (ICSmaleSF).

SF-36 Short Form 36

Dan-PSS Danish Prostatic Symptom Score

EuroQOL-5D European quality of life questionnaire, version 5D

## Potential Harms

Treatments can have harms as well as benefits. In this section, we discuss three categories of potential harms that can be caused by treatments for BPH: perioperative outcomes, adverse events and retreatment. Perioperative outcomes occur during the operation (or soon after), adverse events can occur soon after the operation or after a delay, and retreatment involves the long-term question of whether a treatment ultimately results in the need for additional treatment (due to the lack of benefit or declining benefit). These outcomes are further addressed in the Results sections of this report.

### Perioperative outcomes

Patients receiving certain surgical treatments can require transfusions. Thus, trials often report the number of patients who required transfusions, the amount of blood loss, and the amount of blood that was transfused. Additional intraoperative measures included operation time, anesthesia usage, and the amount of prostate tissue resected. Immediately after the operation, most treatments for BPH require urethral catheterization, so many trials report the number of days that patients were catheterized as well as the length of hospitalization. Some trials also report postoperative changes in serum levels of hemoglobin, hematocrit, sodium, or other variables that are affected by the mixing of irrigation fluids with the patients’ blood during the operation.

### Adverse events

All treatments for BPH are associated with some adverse events. For any treatment decision, one should consider both the frequency and the severity of adverse events. These are weighed against the potential benefits of a treatment. The choice between treatments involves a tradeoff between efficacy and adverse events, in which a treatment with greater efficacy, but more potential adverse events, is compared to an alternative treatment with lower efficacy, but fewer adverse events.

Some events are experienced soon after treatment, whereas others are experienced after a few weeks or months. The commonly reported adverse events of treatments for BPH are listed and described in Table A- 6. Additional potential adverse events include mortality, myocardial infarction, stroke, deep venous thrombosis, fever, impaired ejaculation, and decreased libido. Surgical techniques (such as transurethral resection of the prostate, or TURP) are associated with different categories of adverse events than non-surgical techniques (such as transurethral microwave thermotherapy, or TUMT). For example, some patients experience blood loss requiring transfusion after TURP, but none experience it after TUMT.(6)

Table A- 6 Adverse events

Adverse event | Description
Bladder neck contracture | Shortening of muscle tissue in the bladder neck
Dilutional hyponatremia | Inadequate sodium in the blood
Dysuria | Pain (burning sensation) or difficulty in urination
Impotence | Inability to achieve or maintain an erection
Retrograde ejaculation | Ejaculation in which semen travels backwards towards the bladder
Urinary retention | Inability to initiate urination
Urethral stricture (stenosis) | Narrowing or closing of the urethra
Urinary incontinence | Inability to control the flow of urine, resulting in dribbling.
Urinary tract infection (UTI) | Infection of the urinary tract

### Retreatment

For some patients with BPH, the original treatment does not relieve symptoms or the relief is temporary, and it is necessary to retreat the patient. This provides evidence against the efficacy of the original treatment. If the original treatment had worked, then retreatment would not be necessary. The retreatment can be a repetition of the original treatment, or it can be a different treatment altogether. If one wishes to compare any two treatments, an important consideration is which treatment is associated with a lower (i.e., better) rate of retreatment. A related issue is which treatment is associated with a greater amount of time before retreatment.

Several reviews have argued that retreatment is a useful outcome measure in treatments for BPH.(6,236–238) It is an objective measure of a patient-oriented outcome. Patients care about the need for retreatment because they must endure the persistence of symptoms as well as any adverse events caused by the retreatment.

Despite compelling reasons for measuring retreatment, many trials do not report it. One possible reason for this is the need for sufficient followup time. If a trial has a short followup period, then it is less able to detect patients who require retreatment.

Even if a trial has long-term followup, there may still be difficulties with comparing retreatment rates between treatments. One difficulty concerns patient selection bias. If the patients who received one treatment were systematically different from patients who received the other treatment (e.g., they had more severe symptoms before treatment), then a simple comparison of retreatment rates would be biased. This difficulty can be addressed by randomly assigning patients to treatments. Another difficulty is that treatment failure does not necessarily imply the need for retreatment. Some patients may experience the failure of a treatment, but their symptoms are not severe enough to justify retreatment.