# Executive Summary

## Background

Benign prostatic hyperplasia (BPH) is a condition primarily of middle-aged and elderly men. The frequency of the condition increases with age, so it is found in the majority of very elderly men. Consequently, surgical and medical treatments for BPH are some of the most common therapies administered in all of medical practice. BPH is associated with bothersome lower urinary tract symptoms that may include urgency to urinate, frequent urination, weak stream, straining, and/or the sensation of incomplete bladder emptying. These symptoms affect quality of life and sleeping patterns. Medical therapy is available for BPH; however, this may have undesirable side-effects and may provide inadequate relief for more severe cases.

Open prostatectomy may be used for men with very large prostates, but has been largely replaced by transurethral resection of the prostate (TURP) as the gold standard for surgical treatment of BPH. Transurethral incision of the prostate (TUIP) is considered by some to be an alternative standard for men with small prostates. Devices and techniques similar to TURP are used for transurethral electrovaporization (TUEVP) and transurethral vaporization with resection of the prostate (TUVRP), and these newer techniques have come to be considered variations on the TURP standard.

However, the standard surgeries may be accompanied by undesirable complications of blood loss, transfusion and absorption of irrigation fluids and may result in side-effects such as retrograde ejaculation and incontinence. Therefore, there have been attempts to develop new surgical techniques that use lasers, as well as minimally invasive techniques with heat, microwaves, radiofrequencies, and ultrasound, with the intent of developing techniques that are less invasive than TURP (and thus have fewer complications and side-effects), but provide equivalent symptom relief. It is also desirable that these newer treatments have low retreatment rates. Thus, there are many types of outcomes to examine in comparing these less invasive treatments to TURP. For these less invasive treatments, it may not be a simple question of comparative efficacy with TURP, but rather a question of whether lower complication and side-effect rates are a suitable tradeoff for possibly somewhat less symptom relief and possibly a need for retreatment in the future.

The primary purpose of this technology assessment is to review the evidence comparing newer forms of surgery or minimally invasive treatments to TURP (or other standard surgical variations), in terms of efficacy, complications, side effects, and retreatment rates.

## Methods

ECRI conducted a systematic review of the controlled trial literature on surgical alternatives to standard surgeries for BPH, as well as minimally invasive treatments. These treatments were compared to either the standard surgeries (TURP, open prostatectomy, TUIP, TUEVP, TUVRP), medical therapy, sham, placebo, or no treatment. We searched 17 electronic databases (including Medline and Embase) for relevant articles. These searches were designed to locate all controlled trials of the treatments of interest published since 1975. Searches were conducted in November 2002, and updated in January and May 2003. We also examined the bibliographies of relevant publications. These searches yielded a total of 1,811 citations. Articles that appeared to report on relevant controlled trials (as judged from their abstracts) were retrieved. These articles were read and selected by a priori standards of relevance and quality. This provided an evidence base of 145 articles reporting on 104 separate studies. Trial information and all results at all time points, including figures, were extracted and compiled in evidence tables (Volume II).

From the Evidence Tables, we conducted a systematic, qualitative, best-evidence review, giving greater value to data from studies of larger size, longer followup, and higher quality. While all results were tabled and examined, we emphasized patients’ symptoms as measured by standardized indexes such as the International Prostate Symptom Score (IPSS), Madsen Score, and Boyarsky Score. We also placed some importance on the main objective physiological measures of maximum flow rate (Qmax) and post-void residual volume (PVR). The precise relationship of these measures to patient symptoms is incompletely understood. However, we believe these objective measures are of interest because it is possible they will correlate with long-term symptom results, which are scarce in the literature. We considered retreatment rates (typically with TURP) of major importance, because the less invasive treatments are intended to replace, or at least postpone TURP. We examined complication and side-effect rates, and called out any differences in these rates between the less invasive treatments and TURP.

## Results and Conclusions

### Specific conclusions

- Standard surgical alternatives to TURP include transurethral electrovaporization techniques (TUEVP and TUVRP), open prostatectomy, and transurethral incision of the prostate (TUIP).
- Because electrovaporization involves skills and devices similar to those used in TURP, it can be considered a modification of TURP. Symptoms and peak urinary flow rates are similar after TUEVP, TUVRP and TURP. Quality of life is also similar after TUEVP and TURP. Both hospitalization time and catheterization time are shorter for TUEVP.
- There are no current direct comparisons of open prostatectomy to TURP. Open prostatectomy and TURP are now used on different patient populations. Open prostatectomy remains the preferred option for patients with very large prostates.
- TUIP is a recommended treatment for men with small prostates. TUIP and TURP provide similar symptom relief. TUIP results in lower retrograde ejaculation rates and shorter operation times, as well as shorter catheterization times and hospital stays than TURP. However, TURP results in higher peak urinary flow rates than TUIP.
- Contact laser ablation of the prostate (CLAP) and TURP resulted in similar improvements in physiological measures. CLAP and TURP provided similar symptom relief and similar quality of life improvements in most trials, but one double-blinded RCT found these outcomes to be less improved after CLAP than after TURP. CLAP results in less blood loss than TURP.
- One year after surgery, symptoms and quality of life improvements are similar after visual laser ablation of the prostate (VLAP) and TURP. VLAP requires shorter hospitalizations and longer catheterization times than TURP. Two trials report that major adverse events are less likely after VLAP than after TURP. Three trials report that patients who receive VLAP are more likely to require retreatment than patients who receive TURP.
- One controlled trial reported that symptoms and physiological measures improve to a similar degree after holmium laser ablation of the prostate (HoLAP) and TURP. This RCT also reported that HoLAP operations take longer than TURP operations.
- One trial reported that holmium laser resection of the prostate (HoLRP) and TURP improve symptoms to a similar degree and that HoLRP operations take longer than TURP operations, but require shorter lengths of stay and catheterization times than TURP.
- Two trials reported that after six months, holmium laser enucleation of the prostate (HoLEP) and open prostatectomy yield similar symptom improvement in patients with large prostates. Two trials reported that HoLEP required shorter hospital stays and one trial reported that HoLEP required shorter catheterization times.
- Interstitial laser coagulation (ILC) and TURP generally provide similar improvements in symptoms and quality of life. Results for physiological measures were mixed. Two trials reported higher retreatment rates after ILC. Unlike TURP, ILC may not require any hospitalization time, but this may be offset by a longer catheterization time.
- Hybrid laser techniques are too varied to permit general conclusions about this category of treatment for BPH.
- Radiofrequency needle ablation (RFNA) results in less symptom and physiological improvement than TURP up to 24 months after treatment, and two trials reported that the two treatments have similar effects on quality of life. One trial reported that decreased ejaculate and retrograde ejaculation occur less often after RFNA than after TURP.
- Only one study examined high frequency ultrasound (HIFU), but it was not randomized, and patients in its groups were not comparable.
- Cooling transurethral microwave thermotherapy (TUMT) leads to improved symptoms and physiological measures up to 12 months after treatment. Most trials report that cooling TUMT provides less symptom relief and less improvement in physiological measures than does TURP. One trial reported that retrograde ejaculation was less common after TUMT than after TURP. Retreatment rates may be higher after cooling TUMT than after TURP.
- One RCT reported that non-cooling TUMT may improve symptoms but has associated adverse events. One RCT reported that non-cooling TUMT and TURP yield similar improvements in symptoms and physiological measures, and each has different adverse events.
- One retrospective study reported that fixed stents provide more symptom relief and greater improvements in peak urinary flow rates than spiral stents, transurethral thermotherapy (TUT) and transrectal hyperthermia (TRH).
- TRH, TUT, balloon dilation, and transurethral ultrasound-guided laser-induced prostatectomy (TULIP) are outdated technologies not currently recommended by any professional organization.
- Ethanol ablation, photoselective vaporization of the prostate (PVP) and water-induced thermotherapy (WIT) are emerging therapies not yet studied in controlled trials.

### General conclusions

The purpose of newer treatments for BPH is to approximate the efficacy of TURP and the other standard surgeries while decreasing the potential harms associated with these surgeries. Some of the less invasive treatments do appear to have fewer and/or less severe immediate complications and side effects, and symptom relief approaches that of TURP. Retreatment rates suggest that symptom relief may not be as long lasting as with TURP. However, the published controlled trials are mostly small and short-term, and few of them completely reported retreatment rates (particularly the need for TURP), adverse events, and harms. Long-term effects of these treatments are currently unknown.