# References

1 Holtgrewe HL, Mebust WK, Dowd JB, Cockett AT, Peters PC, Proctor C. Transurethral prostatectomy: practice aspects of the dominant operation in American urology. J Urol. Feb. 1989;141(2):248-253. [pmid: 2643720].
2 Holtgrewe HL. Transurethral prostatectomy. Urol Clin North Am. May. 1995;22(2):357-368. [pmid: 7762111].
3 Roehrborn CG, McConnell JD, Barry MJ, Benaim EA, Blute ML, Bruskewitz R, Holtgrewe HL, Kaplan SA, Lange JL, Lowe FC, Roberts RG, Stein B. AUA guideline on the management of benign prostatic hyperplasia. American Urological Association Education and Research, Inc. 2003. Available: http://www.auanet.org/timssnet/products/guidelines/bph_management.cfm.
4 Warwick RT. A urodynamic review of bladder outlet obstruction in the male and its clinical implications. Urol Clin North Am. Feb. 1979;6(1):171-192. [pmid: 86223].
5 Chatelain C, Denis L, Foo KT, Khoury S, McConnell J, Abrams P, Barry M, Bartsch G, Boyle P, Brawer M, Corriere J, Debruyne F, Dreikorn K, Jardin A, Lee C, Naslund M, Nordling J, Resnick M, Roehrborn C. Recommendations of the International Scientific Committee: evaluation and treatment of lower urinary tract symptoms (LUTS) in older men. Proceedings of the fifth international consultation on BPH. Plymouth (UK). Health Publication Ltd. 2001:519-534.
6 Stoevelaar HJ, McDonnell J. Changing therapeutic regimens in benign prostatic hyperplasia. Clinical and economic considerations. Pharmacoeconomics. 2001;19(2):131-153. [pmid: 11284380].
7 Fitzpatrick JM, Kasidas GP, Rose GA. Hyperoxaluria following glycine irrigation for transurethral prostatectomy. Br J Urol. Jun. 1981;53(3):250-252. [pmid: 7248703].
8 Hoekstra PT, Kahnoski R, McCamish MA, Bergen W, Heetderks DR. Transurethral prostatic resection syndrome--a new perspective: encephalopathy with associated hyperammonemia. J Urol. Oct. 1983;130(4):704-707. [pmid: 6887402].
9 Norlen H, Dimberg M, Allgen LG, Vinnars E. Water and electrolytes in muscle tissue and free amino acids in muscle and plasma in connection with transurethral resection of the prostate. II. Isotonic 2.2% glycine solution as an irrigating fluid. Scand J Urol Nephrol. 1990;24(2):95-101. [pmid: 1694040].
10 Dimberg M, Norlen H, Allgen LG, Allgen T, Wallin M. A comparison between two hypotonic irrigating solutions used in transurethral resections of the prostate: sorbitol (2%)-mannitol (1%) and 1.5% glycine solutions. Scand J Urol Nephrol. 1992;26(3):241-247. [pmid: 1279784].
11 Olsson J, Nilsson A, Hahn RG. Symptoms of the transurethral resection syndrome using glycine as the irrigant. J Urol. Jul. 1995;154(1):123-128. [pmid: 7776407].
12 Hahn RG, Nilsson A, Farahmand BY, Ekengren J, Persson PG. Operative factors and the longterm incidence of acute myocardial infarction after transurethral resection of the prostate. Epidemiology. Jan. 1996;7(1):93-95. [pmid: 8664409].
13 Mebust WK, Holtgrewe HL, Cockett AT, Peters PC. Transurethral prostatectomy: immediate and postoperative complications. A cooperative study of 13 participating institutions evaluating 3,885 patients. J Urol. Feb. 1989;141(2):243-247. [pmid: 2643719].
14 Horninger W, Unterlechner H, Strasser H, Bartsch G. Transurethral prostatectomy: mortality and morbidity. Prostate. Mar. 1996;28(3):195-200. [pmid: 8628722].
15 Donnelly V, Foran A, Murphy J, McParland P, Keane D, O'Herlihy C. Neonatal brachial plexus palsy: an unpredictable injury. Am J Obstet Gynecol. Nov. 2002;187(5):1209-1212. [pmid: 12439505].
16 Madersbacher S, Marberger M. Is transurethral resection of the prostate still justified?. BJU Int. Feb. 1999;83(3):227-237. [pmid: 10233485].
17 Madersbacher S, Djavan B, Marberger M. Minimally invasive treatment for benign prostatic hyperplasia. Curr Opin Urol. 1998;8:17-26. [pmid: 17035837].
18 Gilling PJ, Mackey M, Cresswell M, Kennett K, Kabalin JN, Fraundorfer MR. Holmium laser versus transurethral resection of the prostate: a randomized prospective trial with 1-year followup. J Urol. Nov. 1999;162(5):1640-1644. [pmid: 10524887].
19 Debruyne FM, Djavan B, De la Rosette J, Desgrandchamps F, Fourcade R, Gibbon R, Kaplan S, Hartung R, Krane R, Manyak M, Mebust W, Muschter R, Murai M, Schulman CC, Sedelaar JP, Stein B, Teillac P, Zlotta A. Interventional therapy for benign prostatic hyperplasia. Proceedings of the fifth international consultation on BPH. Plymouth (UK). Health Publication Ltd. 2001:399-421.
20 Barry MJ, Fowler FJ Jr, O'Leary MP, Bruskewitz RC, Holtgrewe HL, Mebust WK, Cockett AT. The American Urological Association symptom index for benign prostatic hyperplasia. The Measurement Committee of the American Urological Association. J Urol. Nov. 1992;148(5):1549-1557. discussion 1564. [pmid: 1279218].
21 Madsen PO, Iversen P. Hinman F Jr, editor. A point system for selecting operative candidates. Benign prostatic hypertrophy. New York. Springer-Verlag. 1983:763-765.
22 Ackerman SJ, Rein AL, Blute M, Beusterien K, Sullivan EM, Tanio CP, Manyak MJ, Strauss MJ. Cost effectiveness of microwave thermotherapy in patients with benign prostatic hyperplasia: part I-methods. Urology. Dec. 20. 2000;56(6):972-980. [pmid: 11113743].
23 Schulz MW, Chen J, Woo HH, Keech M, Watson ME, Davey PJ. A comparison of techniques for eliciting patient preferences in patients with benign prostatic hyperplasia. J Urol. Jul. 2002;168(1):155-159. [pmid: 12050512].
24 Sech SM, Montoya JD, Bernier PA, Barnboym E, Brown S, Gregory A, Roehrborn CG. The so-called 'placebo effect' in benign prostatic hyperplasia treatment trials represents partially a conditional regression to the mean induced by censoring. Urology. 1998;51:242-250. [pmid: 9495705].
25 D'Agostino RB Sr. Non-inferiority trials: advances in concepts and methodology. Stat Med. Jan. 2003;22(2):165-167.
26 D'Agostino RB Sr, Massaro JM, Sullivan LM. Non-inferiority trials: design concepts and issues - the encounters of academic consultants in statistics. Stat Med. Jan. 2003;22(2):169-186. [pmid: 12520555].
27 O'Mallry AJ, Normand ST, Kuntz RE. Application of models for multivariate mixed outcomes to medical device trials: coronary artery stenting. Stat Med. Jan. 2003;22(2):313-336. [pmid: 12520564].
28 Cooper EC. Methodological issues in AIDS clinical trials. Active control equivalence trials. J Acquir Immune Defic Syndr. Suppl 2. 1990;3:S77-S81. [pmid: 2136330].
29 Meeting transcript. Cardiovascular and Renal Drugs Advisory Committee 82nd Meeting. 1997 Oct 23. Bethesda (MD). Rockville (MD). U.S. Food and Drug Administration. Oct. 23. 1997:161. Also available: http://www.fda.gov/ohrms/dockets/ac/97/transcpt/3338t1.pdf.
30 Office of Science Coordination and Communication. Guidance for institutional review boards andclinical investigators. Drugs and biologics. [Internet]. Rockville (MD). U.S. Food and Drug Administration. Sep. cited 2003 Aug 19. 1998:11. Available: http://www.fda.gov/oc/ohrt/irbs/drugsbiologics.html.
31 Hung HM, Wang SJ, Tsong Y, Lawrence J, O'Neil RT. Some fundamental issues with noninferiority testing in active controlled trials. Stat Med. Jan. 2003;22(2):213-225. [pmid: 12520558].
32 Wang SJ, Hung HM. TACT method for non-inferiority testing in active controlled trials. Stat Med. Jan. 2003;22(2):227-238. [pmid: 12520559].
33 Rothmann M, Li N, Chen G, Chi GY, Temple R, Tsoi HH. Design and analysis of non-inferiority mortality trials in oncology. Stat Med. Jan. 2003;22(2):239-264. [pmid: 12520560].
34 Greene WL, Concato J, Feinstein AR. Claims of equivalence in medical research: are theysuppored by the evidence. Ann Intern Med. May. 2000;132(9):715-722. [pmid: 10787365].
35 Vuorinen J. A practical approach for the assessment of bioequivalence under selected higher-order cross-over designs. Stat Med. Oct. 15. 1997;16(19):2229-2243. [pmid: 9330430].
36 Makuch R, Johnson M. Issues in planning and interpreting active control equivalence studies. J Clin Epidemiol. 1989;42(6):503-511. [pmid: 2661729].
37 Haines SJ, Walters BC. Proof of equivalence. The inference of statistical significance. Caveat emptor [editorial]. Neurosurgery. Sep. 1993;33(3):432-433. [pmid: 8413874].
38 Djavan B. Benign prostatic hyperplasia: where do we stand in the new millennium?. Curr OpinUrol. 2002;12:1-2.
39 Littlejohn JO Jr, Ghafar MA, Kang YM, Kaplan SA. Transurethral resection of the prostate: the new old standard. Curr Opin Urol. Jan. 2002;12(1):19-23. [pmid: 11753129].
40 May F, Guenther M, Fastenmeier K, Hartung R. Improved high-frequency surgery for transurethral resection of the prostate: report from a multicenter trial and identification of risk groups [abstract ID: 101757]. 2003 AUA annual meeting. 2003 Apr 26-May 1. Chicago (IL). Baltimore (MD). American Urological Association. 2003. Also available: http://aua03.agora.com/planner/displayabstract.asp?presentationid=1729.
41 Tucker RD, Sievert CE, Kramolowsky EV, Vennes JA, Silvis SE. The interaction between electrosurgical generators, endoscopic electrodes, and tissue. Gastrointest Endosc. Mar-Apr. 1992;38(2):118-122. [pmid: 1568605].
42 Grundy PL, Budd DW, England R. A randomized controlled trial evaluating the use of sterile water as an irrigation fluid during transurethral electrovaporization of the prostate. Br J Urol. Dec. 1997;80(6):894-897. [pmid: 9439404].
43 Kursh ED, Concepcion R, Chan S, Hudson P, Ratner M, Eyre R. Interstitial laser coagulation versus transurethral prostate resection for treating benign prostatic obstruction: a randomized trial with 2-year follow-up. Urology. Mar. 2003;61(3):573-578. [pmid: 12639650].
44 Cetinkaya M, Ulusoy E, Ozturk B, Inal G, Memis A, Akdemir O. Transurethral resection or electrovaporization in the treatment of BPH. Br J Urol. Apr. 1998;81(4):652-654. [pmid: 9598658].
45 Borboroglu PG, Kane CJ, Ward JF, Roberts JL, Sands JP. Immediate and postoperative complications of transurethral prostatectomy in the 1990s. J Urol. Oct. 1999;162(4):1307-1310. [pmid: 10492185].
46 Meyhoff HH. Transurethral versus transvesical prostatectomy. Clinical, urodynamic, renographic and economic aspects. A randomized study. Scand J Urol Nephrol Suppl. 1987;102:1-26. [pmid: 2434990].
47 Deckert T, Yokoyama H, Mathiesen E, Ronn B, Jensen T, Feldt-Rasmussen B, Borch-Johnsen K, Jensen JS. Cohort study of predictive value of urinary albumin excretion for atherosclerotic vascular disease in patients with insulin dependent diabetes. BMJ. Apr. 6. 1996;312(7035):871-874. [pmid: 8611873].
48 Proceedings of the fifth international consultation on BPH. Plymouth (UK). Health Publication Ltd. 2001:535.
49 de la Rosette JJ, Alivizatos G, Madersbacher S, Perachino M, Thomas D, Desgrandchamps F, de Wildt M. EAU Guidelines on benign prostatic hyperplasia (BPH). Eur Urol. Sep. 2001;40(3):256-263. discussion 264. [pmid: 11684840].
50 Kaplan SA, Laor E, Fatal M, Te AE. Transurethral resection of the prostate versus transurethral electrovaporization of the prostate: a blinded, prospective comparative study with 1-year followup. J Urol. Feb. 1998;159(2):454-458. [pmid: 9649262].
51 Netto NR Jr, De Lima ML, Lucena R, Lavoura NS, Cortado PL, Netto MR. Is transurethral vaporization a remake of transurethral resection of the prostate. J Endourol. Oct. 1999;13(8):591-594. [pmid: 10597132].
52 Hammadeh MY, Madaan S, Singh M, Philp T. Two-year follow-up of a prospective randomised trial of electrovaporization versus resection of prostate. Eur Urol. Sep. 1998;34(3):188-192. [pmid: 9732190].
53 Cabelin MA, Te AE, Kaplan SA. Transurethral vaporization of the prostate: current techniques. Curr Urol Rep. Jul. 2000;1(2):116-123. [pmid: 12084325].
54 van Swol CF, van Vliet RJ, Verdaasdonk RM, Boon TA. Electrovaporization as a treatmentmodality for transurethral resection of the prostate: influence of generator type. Urology. Feb. 1999;53(2):317-321. [pmid: 9933047].
55 Talic RF, El Tiraifi A, El Faqih SR, Hassan SH, Attassi RA, Abdel-Halim RE. Prospective randomized study of transurethral vaporization resection of the prostate using the thick loop and standard transurethral prostatectomy. Urology. Jun. 2000;55(6):886-890. discussion 890-1. [pmid: 10840101].
56 American Urological Association, AUA BPH Guideline Update Panel. Management of BPH (2003). Baltimore (MD). American Urological Association Education and Research, Inc. 2003:315. Also available: http://shop.auanet.org/timssnet/products/guidelines/bph_management.cfm.
57 Helke C, Manseck A, Hakenberg OW, Wirth MP. Is transurethral vaporesection of the prostate better than standard transurethral resection. Eur Urol. May. 2001;39(5):551-557. [pmid: 11464036].
58 Kupeli S, Yilmaz E, Soygur T, Budak M. Randomized study of transurethral resection of the prostate and combined transurethral resection and vaporization of the prostate as a therapeutic alternative in men with benign prostatic hyperplasia. J Endourol. Apr. 2001;15(3):317-321. [pmid: 11339401].
59 Cetinkaya M, Ozturk B, Akdemir O, Aki FT. A comparison of fluid absorption during transurethral resection and transurethral vaporization for benign prostatic hyperplasia. BJU Int. Nov. 2000;86(7):820-823. [pmid: 11071682].
60 Ekengren J, Haendler L, Hahn RG. Clinical outcome 1 year after transurethral vaporization and resection of the prostate. Urology. Feb. 2000;55(2):231-235. [pmid: 10688085].
61 Hammadeh MY, Madaan S, Singh M, Philp T. A 3-year follow-up of a prospective randomized trial comparing transurethral electrovaporization of the prostate with standard transurethral prostatectomy. BJU Int. Oct. 2000;86(6):648-651. [pmid: 11069371].
62 Hammadeh MY, Fowlis GA, Singh M, Philp T. Transurethral electrovaporization of the prostate-a possible alternative to transurethral resection: a one-year follow-up of a prospective randomized trial. Br J Urol. May. 1998;81(5):721-725. [pmid: 9634048].
63 Schatzl G, Madersbacher S, Djavan B, Lang T, Marberger M. Two-year results of transurethral resection of the prostate versus four 'less invasive' treatment options. Eur Urol. Jun. 2000;37(6):695-701. [pmid: 10828670].
64 Schatzl G, Madersbacher S, Lang T, Marberger M. The early postoperative morbidity of transurethral resection of the prostate and of 4 minimally invasive treatment alternatives. J Urol. Jul. 1997;158(1):105-110. 110. 111. [pmid: 9186334].
65 Erdagi U, Akman RY, Sargin SY, Yazicioglu A. Transurethral electrovaporization of the prostate versus transurethral resection of the prostate: a prospective randomized study. Arch Ital Urol Androl. Jun. 1999;71(3):125-130. [pmid: 10431402].
66 Gotoh M, Okamura K, Hattori R, Nishiyama N, Kobayashi H, Tanaka K, Yamada S, Kato T, Kinukawa T, Ono Y, Ohshima S. A randomized comparative study of the Bandloop versus the standard loop for transurethral resection of the prostate. J Urol. Nov. 1999;162(5):1645-1647. [pmid: 10524888].
67 Cetinkaya M, Ulusoy E, Adsan O, Saglam H, Ozturk B, Basay S. Comparative early results of transurethral electroresection and transurethral electrovaporization in benign prostatic hyperplasia. Br J Urol. Dec. 1996;78(6):901-903. [pmid: 9014716].
68 Gallucci M, Puppo P, Perachino M, Fortunato P, Muto G, Breda G, Mandressi A, Comeri G, Boccafoschi C, Francesca F, Guazzieri S, Pappagallo GL. Transurethral electrovaporization of the prostate vs. transurethral resection. Results of a multicentric, randomized clinical study on 150 patients. Eur Urol. 1998;33(4):359-364. [pmid: 9612677].
69 Kupeli B, Yalcinkaya F, Topaloglu H, Karabacak O, Gunlusoy B, Unal S. Efficacy of transurethral electrovaporization of the prostate with respect to standard transurethral resection. J Endourol. Dec. 1998;12(6):591-594. [pmid: 9895267].
70 Shokeir AA, al-Sisi H, Farage YM, el-Maaboud MA, Saeed M, Mutabagani H. Transurethral prostatectomy: a prospective randomized study of conventional resection and electrovaporization in benign prostatic hyperplasia. Br J Urol. Oct. 1997;80(4):570-574. [pmid: 9352695].
71 Van Melick HH, Van Venrooij GE, Eckhardt MD, Boon TA. A randomized controlled trial comparing transurethral resection of the prostate, contact laser prostatectomy and electrovaporization in men with benign prostatic hyperplasia: urodynamic effects. J Urol. Sep. 2002;168(3):1058-1062. [pmid: 12187222].
72 Meyhoff HH, Nordling J, Hald T. Urodynamic evaluation of transurethral versus transvesical prostatectomy. A randomized study. Scand J Urol Nephrol. 1984;18(1):27-35. [pmid: 6201999].
73 Orandi A. Transurethral incision of prostate compared with transurethral resection of prostate in 132 matching cases. J Urol. Oct. 1987;138(4):810-815. [pmid: 2443728].
74 Saporta L, Aridogan IA, Erlich N, Yachia D. Objective and subjective comparison of transurethral resection, transurethral incision and balloon dilatation of the prostate. A prospective study. Eur Urol. 1996;29(4):439-445. [pmid: 8791051].
75 Riehmann M, Knes JM, Heisey D, Madsen PO, Bruskewitz RC. Transurethral resection versus incision of the prostate: a randomized, prospective study. Urology. May. 1995;45(5):768-775. [pmid: 7538238].
76 Jahnson S, Dalen M, Gustavsson G, Pedersen J. Transurethral incision versus resection of the prostate for small to medium benign prostatic hyperplasia. Br J Urol. Feb. 1998;81(2):276-281. [pmid: 9488072].
77 Dorflinger T, Jensen FS, Krarup T, Walter S. Transurethral prostatectomy compared with incision of the prostate in the treatment of prostatism caused by small benign prostate glands. Scand J Urol Nephrol. 1992;26(4):333-338. [pmid: 1284003].
78 Dorflinger T, Oster M, Larsen JF, Walter S, Krarup T. Transurethral prostatectomy or incision of the prostate in the treatment of prostatism caused by small benign prostates. Scand J Urol Nephrol Suppl. 1987;104:77-81. [pmid: 2449724].
79 Soonawalla PF, Pardanani DS. Transurethral incision versus transurethral resection of the prostate. A subjective and objective analysis. Br J Urol. Aug. 1992;70(2):174-177. [pmid: 1382793].
80 Christensen MM, Aagaard J, Madsen PO. Transurethral resection versus transurethral incision of the prostate. A prospective randomized study. Urol Clin North Am. Aug. 1990;17(3):621-630. [pmid: 2197772].
81 Larsen EH, Dorflinger T, Gasser C, Graversen PH, Bruskewitz RC. Transurethral incision versus transurethral resection of the prostate for treatment of benign prostatic hypertrophy, a preliminary report. Scand J Urol Nephrol. suppl 104. 1987;21:83-86.
82 D'Ancona CA, Netto NR Junior, Cara AM, Ikari O. Internal urethrotomy of the prostatic urethra or transurethral resection in benign prostatic hyperplasia. J Urol. Oct. 1990;144(4):918-920. [pmid: 1697916].
83 Nielsen HO. Transurethral prostatotomy versus tranurethral prostatectomy in benign prostatic hypertrophy. A prospective randomized study. Br J Urol. 1988;61:435-438. [pmid: 2456122].
84 Li MK, Ng AS. Bladder neck resection and transurethral resection of the prostate: a randomized prospective trial. J Urol. Oct. 1987;138(4):807-809. [pmid: 2443727].
85 Hellstrom P, Lukkarinen O, Kontturi M. Bladder neck incision or transurethral electroresection for the treatment of urinary obstruction caused by a small benign prostate? A randomized urodynamic study. Scand J Urol Nephrol. 1986;20(3):187-192. [pmid: 2431461].
86 Kitagawa M, Furuse H, Fukuta K, Aso Y. Holmium:YAG laser resection of the prostate versus visual laser ablation of the prostate and transurethral ultrasound-guided laser induced prostatectomy: a retrospective comparative study. Int J Urol. Mar. 1998;5(2):152-156. [pmid: 9559841].
87 Keoghane SR, Cranston DW, Lawrence KC, Doll HA, Fellows GJ, Smith JC. The Oxford Laser Prostate Trial: a double-blind randomized controlled trial of contact vaporization of the prostate against transurethral resection; preliminary results. Br J Urol. Mar. 1996;77(3):382-385. [pmid: 8814842].
88 U.S. Food and Drug Administration, Center for Devices and Radiological Health. 510(k) summary of safety and effectiveness. SLT CL MD contact laser system and delivery fibers. K972548. Rockville (MD). U.S. Food and Drug Administration, Center for Devices and Radiological Health. Apr. 28. 1998:4. Also available: http://www.fda.gov.
89 Tuhkanen K, Heino A, Ala-Opas M. Contact laser prostatectomy compared to TURP in prostatic hyperplasia smaller than 40 ml Six-month follow-up with complex urodynamic assessment. Scand J Urol Nephrol. Feb. 1999;33(1):31-34. [pmid: 10100361].
90 Zorn BH, Bauer JJ, Ruiz HE, Thrasher JB. Randomized trial of safety and efficacy of transurethral resection of the prostate using contact laser versus electrocautery. Tech Urol. Dec. 1999;5(4):198-201. [pmid: 10591258].
91 Keoghane SR, Lawrence KC, Gray AM, Doll HA, Hancock AM, Turner K, Sullivan ME, Dyar O, Cranston D. A double-blind randomized controlled trial and economic evaluation of transurethral resection vs contact laser vaporization for benign prostatic enlargement: a 3-year follow-up. BJU Int. Jan. 2000;85(1):74-78. [pmid: 10619950].
92 Keoghane SR, Doll HA, Lawrence KC, Jenkinson CP, Cranston DW. The Oxford Laser Prostate Trial: sexual function data from a randomized controlled clinical trial of contact laser prostatectomy. Eur Urol. 1996;30(4):424-428. [pmid: 8977062].
93 Jenkinson C, Gray A, Doll H, Lawrence K, Keoghane S, Layte R. Evaluation of index and profile measures of health status in a randomized controlled trial. Comparison of the medical outcomes study 36-item short form health survey, EuroQol, and disease specific measures. Med Care. Nov. 1997;35(11):1109-1118. [pmid: 9366890].
94 Keoghane SR, Lawrence KC, Jenkinson CP, Doll HA, Chappel DB, Cranston DW. The Oxford Laser Prostate Trial: sensitivity to change of three measures of outcome. Urology. Jan. 1996;47(1):43-47. [pmid: 8560661].
95 Suvakovic N, Hindmarsh JR. A step towards day case prostatectomy. Br J Urol. Feb. 1996;77(2):212-214. [pmid: 8800888].
96 Cowles RS 3d, Kabalin JN, Childs S, Lepor H, Dixon C, Stein B, Zabbo A. A prospective randomized comparison of transurethral resection to visual laser ablation of the prostate for the treatment of benign prostatic hyperplasia. Urology. Aug. 1995;46(2):155-160. [pmid: 7542818].
97 Jung P, Mattelaer P, Wolff JM, Mersdorf A, Jakse G. Visual laser ablation of the prostate: efficacy evaluated by urodynamics and compared to TURP. Eur Urol. 1996;30(4):418-423. [pmid: 8977061].
98 Costello AJ, Crowe HR, Jackson T, Street A. A randomised single institution study comparing laser prostatectomy and transurethral resection of the prostate. Ann Acad Med Singapore. Sep. 1995;24(5):700-704. [pmid: 8579313].
99 Anson K, Nawrocki J, Buckley J, Fowler C, Kirby R, Lawrence W, Paterson P, Watson G. A multicenter, randomized, prospective study of endoscopic laser ablation versus transurethral resection of the prostate. Urology. Sep. 1995;46(3):305-310. [pmid: 7544932].
100 Donovan JL, Peters TJ, Neal DE, Brookes ST, Gujral S, Chacko KN, Wright M, Kennedy LG, Abrams P. A randomized trial comparing transurethral resection of the prostate, laser therapy and conservative treatment of men with symptoms associated with benign prostatic enlargement: The CLasP study. J Urol. Jul. 2000;164(1):65-70. [pmid: 10840426].
101 Gujral S, Abrams P, Donovan JL, Neal DE, Brookes ST, Chacko KN, Wright MJ, Timoney AG, Peters TJ. A prospective randomized trial comparing transurethral resection of the prostate and laser therapy in men with chronic urinary retention: The CLasP study. J Urol. Jul. 2000;164(1):5964.
102 Chacko KN, Donovan JL, Abrams P, Peters TJ, Brookes ST, Thorpe AC, Gujral S, Wright M, Kennedy LG, Neal DE. Transurethral prostatic resection or laser therapy for men with acute urinary retention: the CLasP randomized trial. J Urol. 2001;166(1):166-170. [pmid: 11435848].
103 Sengor F, Kose O, Yucebas E, Beysel M, Erdogan K, Narter F. A comparative study of laser ablation and transurethral electroresection for benign prostatic hyperplasia: results of a 6-month follow-up [published erratum appears in Br J Urol 1997 Feb;79(2):304]. Br J Urol. Sep. 1996;78(3):398-400. [pmid: 8881949].
104 Brookes ST, Donovan JL, Peters TJ, Abrams P, Neal DE. Sexual dysfunction in men after treatment for lower urinary tract symptoms: evidence from randomised controlled trial. BMJ. May. 4. 2002;324(7345):1059-1061. [pmid: 11991908].
105 Noble SM, Coast J, Brookes S, Neal DE, Abrams P, Peters TJ, Donovan JL. Transurethral prostate resection, noncontact laser therapy or conservative management in men with symptoms of benign prostatic enlargement? An economic evaluation. J Urol. Dec. 01. 2002;168(6):2476-2482. [pmid: 12441944].
106 Kabalin JN. Laser prostatectomy performed with a right angle firing neodymium:YAG laser fiber at 40 watts power setting. J Urol. Jul. 1993;150(1):95-99. [pmid: 7685429].
107 Boon TA, Lepor H, Muschter R, McCullough DL. Laser treatment of benign prostatic hyperplasia (BPH) workshop. Prog Clin Biol Res. 1994;386:535-544. [pmid: 7528425].
108 Kabalin JN, Gill HS, Bite G, Wolfe V. Comparative study of laser versus electrocautery prostatic resection: 18-month followup with complex urodynamic assessment. J Urol. Jan. 1995;153(1):94-97. discussion 97-8. [pmid: 7526006].
109 Shingleton WB, Farabaugh P, May W. Three-year follow-up of laser prostatectomy versus transurethral resection of the prostate in men with benign prostatic hyperplasia. Urology. Aug. 2002;60(2):305-308. [pmid: 12137831].
110 Bryan NP, Hastie KJ, Chapple CR. Randomised prospective trial of contact laser prostatectomy (CLAP) versus visual laser coagulation of the prostate (VLAP) for the treatment of benign prostatic hyperplasia. 2-year follow-up. Eur Urol. Sep. 2000;38(3):265-271. [pmid: 10940699].
111 Narayan P, Tewari A, Aboseif S, Evans C. A randomized study comparing visual laser ablation and transurethral evaporation of prostate in the management of benign prostatic hyperplasia. J Urol. Dec. 1995;154(6):2083-2088. [pmid: 7500464].
112 Beerlage HP, Francisca EA, d'Ancona FC, Debruyne FM, De la Rosette JJ. Urolase v ultraline fibers in laser prostatectomy: 3-year follow-up of a randomized study. J Endourol. Dec. 1998;12(6):575-580. [pmid: 9895265].
113 de la Rosette JJ, te Slaa E, de Wildt MJ, Debruyne FM. Experience with the Ultraline and Urolase laser fibers: is there any difference. World J Urol. 1995;13(2):98-103. [pmid: 7542973].
114 de la Rosette J. Laser therapy: to combine the best of the new with the best of the old. J Urol (Paris). 1995;101(1):37-39. [pmid: 7545726].
115 Tan AH, Gilling PJ. Holmium laser prostatectomy: current techniques. Urology. Jul. 2002;60(1):152-156. [pmid: 12100945].
116 Paterson RF, Lingeman JE. Holmium laser prostatectomy. Curr Urol Rep. Aug. 2001;2(4):269-276. [pmid: 12084251].
117 Hettiarachchi JA, Samadi AA, Konno S, Das AK. Holmium laser enucleation for large (greater than 100 mL) prostate glands. Int J Urol. May. 2002;9(5):233-236. [pmid: 12060433].
118 CDRH 510(k) database search. [internet]. Rockville (MD). U.S. Food and Drug Administration (FDA), Center for Devices and Radiological Health (CDRH). [updated 2003 Sep 05]; [cited 2003 Sep 08]. Available: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfPMN/pmn.cfm.
119 Mottet N, Anidjar M, Bourdon O, Louis JF, Teillac P, Costa P, Le Duc A. Randomized comparison of transurethral electroresection and Holmium:YAG laser vaporization for symptomatic benign prostatic hyperplasia. J Endourol. Mar. 1999;13(2):127-130. [pmid: 10213108].
120 Gilling PJ, Cass CB, Malcolm A, Cresswell M, Fraundorfer MR, Kabalin JN. Holmium laser resection of the prostate versus neodymium:yttrium-aluminum-garnet visual laser ablation of the prostate: a randomized prospective comparison of two techniques for laser prostatectomy. Urology. Apr. 1998;51(4):573-577. [pmid: 9586609].
121 Fraundorfer MR, Gilling PJ, Kennett KM, Dunton NG. Holmium laser resection of the prostate is more cost effective than transurethral resection of the prostate: results of a randomized prospective study. Urology. Mar. 2001;57(3):454-458. [pmid: 11248619].
122 Gilling PJ, Kennett KM, Fraundorfer MR. Holmium laser resection v transurethral resection of the prostate: results of a randomized trial with 2 years of follow-up. J Endourol. Nov. 2000;14(9):757-760. [pmid: 11110572].
123 Kuntz RM, Lehrich K. Transurethral holmium laser enucleation versus transvesical open enucleation for prostate adenoma greater than 100 gm.: a randomized prospective trial of 120 patients. J Urol. Oct. 2002;168(4 Pt 1):1465-1469. [pmid: 12352419].
124 Moody JA, Lingeman JE. Holmium laser enucleation for prostate adenoma greater than 100 gm.: comparison to open prostatectomy. J Urol. Feb. 2001;165(2):459-462. [pmid: 11176396].
125 Perlmutter AP, Muschter R. Interstitial laser prostatectomy. Mayo Clin Proc. Sep. 1998;73(9):903-907. [pmid: 9737231].
126 Muschter R. Interstitial laser therapy. Curr Opin Urol. 1996;6:33-38.
127 Pypno W, Husiatynski W. Treatment of a benign prostatic hyperplasia by Nd:YAG laser – own experience. Eur Urol. Aug. 2000;38(2):194-198. [pmid: 10895012].
128 Martenson AC, De la Rosette JJMCH. Interstitial laser coagulation in the treatment of benign prostatic hyperplasia using a diode laser system: results of an evolving technology. Prostate Cancer Prostatic Dis. 1999;2(3):148-154. [pmid: 12496824].
129 Norby B, Nielsen HV, Frimodt-Moller PC. Transurethral interstitial laser coagulation of the prostate and transurethral microwave thermotherapy vs transurethral resection or incision of the prostate: results of a randomized, controlled study in patients with symptomatic benign prostatic [tr. BJU Int. Dec. 2002;90(9):853-862. [pmid: 12460345].
130 Arai Y, Aoki Y, Okubo K, Maeda H, Terada N, Matsuta Y, Maekawa S, Ogura K. Impact of interventional therapy for benign prostatic hyperplasia on quality of life and sexual function: a prospective study. J Urol. Oct. 2000;164(4):1206-1211. [pmid: 10992367].
131 Fenter TC. (American Urological Association). Personal communication. 2004. Mar. 4.
132 Shingleton WB, Terrell F, Renfroe DL, Kolski JM, Fowler JE Jr. A randomized prospective study of laser ablation of the prostate versus transurethral resection of the prostate in men with benign prostatic hyperplasia. Urology. Dec. 1999;54(6):1017-1021. [pmid: 10604701].
133 Tuhkanen K, Heino A, Ala-Opas M. Two-year follow-up results of a prospective randomized trial comparing hybrid laser prostatectomy with TURP in the treatment of big benign prostates. Scand J Urol Nephrol. Jun. 2001;35(3):200-204. [pmid: 11487072].
134 Tuhkanen K, Heino A, Alaopas M. Hybrid laser treatment compared with transurethral resection of the prostate for symptomatic bladder outlet obstruction caused by a large benign prostate: a prospective, randomized trial with a 6-month follow-up. BJU Int. Nov. 1999;84(7):805-809. [pmid: 10532976].
135 Carter A, Sells H, Speakman M, Ewings P, MacDonagh R, O'Boyle P. A prospective randomized controlled trial of hybrid laser treatment or transurethral resection of the prostate, with a 1-year follow-up. BJU Int. Feb. 1999;83(3):254-259. [pmid: 10233489].
136 Carter A, Sells H, Speakman M, Ewings P, O'Boyle P, MacDonagh R. Quality of life changes following KTP/Nd:YAG laser treatment of the prostate and TURP. Eur Urol. Aug. 1999;36(2):92-98. [pmid: 10420027].
137 Shingleton WB, Renfroe LD, Kolski JM, Fowler JE Jr. A randomized prospective study of transurethral electrovaporization vs laser ablation of the prostate in men with benign prostatic hypertrophy. Scand J Urol Nephrol. Jul. 1998;32(4):266-269. [pmid: 9764453].
138 Shingleton WB, Kolski J, Renfroe DL, Fowler JE Jr. Electrovaporization of the prostate versus laser ablation of the prostate in men with benign prostatic hypertrophy: a pressure-flow analysis. Urol Int. Aug. 1998;60(4):224-228. [pmid: 9701735].
139 Gilling PJ, Cass CB, Malcolm AR, Fraundorfer MR. Combination holmium and Nd:YAG laser ablation of the prostate: initial clinical experience. J Endourol. Apr. 1995;9(2):151-153. [pmid: 7633476].
140 Malek RS, Hai MA, Nseyo UO, Lapeyrolerie J. Photoselective vaporization of the prostate: breakthrough treatment for BPH. Urol Times. May. Suppl 1. 2002;30:4-20.
141 Giannakopoulos X, Grammeniatis E, Gartzios A, et al. Transurethral needle ablation (TUNA) of the prostate: preliminary results using the new generation TUNA III catheter on patients with symptomatic BPH controlled by a series of 50 patients using TUNA II device. Eur Urol. 1996;30:986.
142 Heaton JP. Radiofrequency thermal ablation of the prostate: the TUNA technique. Tech Urol. Spring. 1995;1(1):3-10. [pmid: 9118364].
143 Chapple CR, Issa MM, Woo H. Transurethral needle ablation (TUNA&reg;). A critical review of radiofrequency thermal therapy in the management of benign prostatic hyperplasia. Eur Urol. 1999;35(2):119-128. [pmid: 9933805].
144 Issa MM, Myrick SE, Symbas NP. The TUNA procedure for BPH: review of technology. Infect Urol. 1998;11(4):104-111. Also available: http://www.medscape.com/SCP/IIU/1998/v11.n04/u3086.issa/pnt-u3086.issa.html.
145 Montie JE, Tremper K. Anesthesia requirements during transurethral needle ablation procedure [letter; comment]. Urology. Jul. 1998;52(1):158. [pmid: 9671891].
146 Zlotta AR, Djavan B. Minimally invasive therapies for benign prostatic hyperplasia in the new millennium: long-term data. Curr Opin Urol. Jan. 2002;12(1):7-14. [pmid: 11753127].
147 Bruskewitz R, Issa MM, Roehrborn CG, Naslund MJ, Perez-Marrero R, Shumaker BP, Oesterling JE. A prospective, randomized 1-year clinical trial comparing transurethral needle ablation to transurethral resection of the prostate for the treatment of symptomatic benign prostatic hyperplasia. J Urol. May. 1998;159(5):1588-1593. discussion 1593-4. [pmid: 9554360].
148 Roehrborn CG, Burkhard FC, Bruskewitz RC, Issa MM, Perez-Marrero R, Naslund MJ, Shumaker BP. The effects of transurethral needle ablation and resection of the prostate on pressure flow urodynamic parameters: analysis of the United States randomized study. J Urol. Jul. 1999;162(1):92-97. [pmid: 10379748].
149 Mostafid AH, Harrison NW, Thomas PJ, Fletcher MS. A prospective randomized trial of interstitial radiofrequency therapy versus transurethral resection for the treatment of benign prostatic hyperplasia. Br J Urol. Jul. 1997;80(1):116-122. [pmid: 9240190].
150 Hill B, Belville W, Bruskewitz R, Issa M, Perez-Marrero R, Roehrborn C, Terris M, Naslund M. Transurethral needle ablation versus transurethral resection of the prostate for the treatment of symptomatic benign prostatic hyperplasia: 5-year results of a prospective, randomized, multicenter clinical trial. J Urol. Jun. 2004;171(6 Pt 1):2336-2340. [pmid: 15126816].
151 Focus Surgery. Noninvasive therapy for prostate diseases: Focus surgery has positive prostate cancer results using high intensity focused ultrasound (HIFU). [internet]. Indianapolis (IN). Focus Surgery, Inc. cited 2003 Sep 09. 2003:2. Available: http://www.focus-surgery.com.
152 Premarket approval (PMA) database for Urologix Targis (tm) system. P970008. [internet]. Rockville (MD). U.S. Food and Drug Administration, Center for Devices and Radiological Health (CDRH). Dec. 16. cited 2003 Sep 02. 1999:1. Available: http://www.accessdata.fda.gov.
153 Premarket approval (PMA) database for Prostatron system, hyperthermia. P950014. [internet]. Rockville (MD). U.S. Food and Drug Administration, Center for Devices and Radiological Health (CDRH). Nov. 26. cited 2003 Sep 02. 1999:1. Available: http://www.accessdata.fda.gov.
154 Urologix. Prostatron treatment. [internet]. Minneapolis (MN). Urologix, Inc. cited 2003 Aug 12. 2003:1. Available: http://www.urologix.com.
155 Lingeman J. Thermotherapy evolves beyond cooling: the logic behind the next generation devices. [internet]. Northbrook (IL). Thermatrx. cited 2003 Sep 02. 2002:2. Available: http://www.thermatrx.com.
156 Larson TR, Blute ML, Tri JL, Whitlock SV. Contrasting heating patterns and efficiency of the Prostatron and Targis microwave antennae for thermal treatment of benign prostatic hyperplasia. Urology. Jun. 1998;51(6):908-915. [pmid: 9609625].
157 Rivas DA, Bagley D, Gomella LG, Hirsch IH, Hubert C, Lombardo S, McGinnis DE, Mulholland SG, Shenot PJ, Strup SE, Vasavada SP. Transurethral microwave thermotherapy of the prostate without intravenous sedation: results of a single United States center using both low- and high-energy protocols. TJUH TUMT Study Group. Tech Urol. Dec. 2000;6(4):282-287. [pmid: 11108567].
158 Center for Devices and Radiological Health (CDRH). FDA public health notification: serious injuries from microwave thermotherapy for benign prostatic hyperplasia. [internet]. Rockville (MD):. U.S. Food and Drug Administration. Oct. 11. cited 2003 Jan 27. 2000:3. Available: http://www.fda.gov/cdrh/safety.html.
159 Roehrborn CG, Preminger G, Newhall P, Denstedt J, Razvi H, Chin LJ, Perlmutter A, Barzell W, Whitmore W, Fritzsch R, Sanders J, Sech S, Womack S. Microwave thermotherapy for benign prostatic hyperplasia with the Dornier Urowave: results of a randomized, double-blind, multicenter, sham-controlled trial. Urology. Jan. 1998;51(1):19-28.
160 Venn SN, Montgomery BS, Sheppard SA, Hughes SW, Beard RC, Bultitiude MI, Lloyd-Davies RW, Tiptaft RC. Microwave hyperthermia in benign prostatic hypertrophy: a controlled clinical trial. Br J Urol. Jul. 1995;76(1):73-76. [pmid: 7544207].
161 Bdesha AS, Bunce CJ, Snell ME, Witherow RO. A sham controlled trial of transurethral microwave therapy with subsequent treatment of the control group. J Urol. Aug. 1994;152(2 Pt 1):453-458. [pmid: 7516979].
162 Bdesha AS, Bunce CJ, Kelleher JP, Snell ME, Vukusic J, Witherow RO. Transurethral microwave treatment for benign prostatic hypertrophy: a randomised controlled clinical trial. BMJ. May. 15. 1993;306(6888):1293-1296. [pmid: 7686065].
163 Laduc R. Thermotherapy. Results of a prospective, randomized, double blind, placebo controlled study. In: Laduc R, Weil EH, Zerbib M, Perrin P, Denis L. Thermotherapy and hyperthermia workshop. Prog Clin Biol Res. 1994;386:487-498. [pmid: 7528419].
164 Mulvin D, Creagh T, Kelly D, Smith J, Quinlan D, Fitzpatrick J. Transurethral microwave thermotherapy versus transurethral catheter therapy for benign prostatic hyperplasia. Eur Urol. 1994;26(1):6-9. [pmid: 7523132].
165 Perrin P. TUMT versus sham in BPH patients. Laduc R, Weil EH, Zerbib M, Perrin P, 32 Denis L. Thermotherapy and hyperthermia workshop. Prog Clin Biol Res. 1994;386:487-498. [pmid: 7528419].
166 Ogden CW, Reddy P, Johnson H, Ramsay JW, Carter SS. Sham versus transurethral microwave thermotherapy in patients with symptoms of benign prostatic bladder outflow obstruction. Lancet. Jan. 2. 1993;341(8836):14-17. [pmid: 7678047].
167 Hansen MV, Zdanowski A. The use of a simple home flow test as a quality indicator for male patients treated for lower urinary tract symptoms suggestive of bladder outlet obstruction. Eur Urol. 1997;32(1):34-38. [pmid: 9266229].
168 Trachtenberg J, Roehrborn CG. Updated results of a randomized, double-blind, multicenter shamcontrolled trial of microwave thermotherapy with the Dornier Urowave in patients with symptomatic benign prostatic hyperplasia. Urowave Investigators Group. World J Urol. 1998;16(2):102-108. [pmid: 12080961].
169 Larson TR, Blute ML, Bruskewitz RC, Mayer RD, Ugarte RR, Utz WJ. A high-efficiency microwave thermoablation system for the treatment of benign prostatic hyperplasia: results of a randomized, sham-controlled, prospective, double-blind, multicenter clinical trial. Urology. May. 1998;51(5):731-742. [pmid: 9610586].
170 Blute ML, Patterson DE, Segura JW, Tomera KM, Hellerstein DK. Transurethral microwave thermotherapy v sham treatment: double-blind randomized study. J Endourol. Dec. 1996;10(6):56573.
171 Francisca EA, d'Ancona FC, Hendriks JC, Kiemeney LA, Debruyne FM, de la Rosette JJ. Quality of life assessment in patients treated with lower energy thermotherapy (Prostasoft 2.0): results of a randomized transurethral microwave thermotherapy versus sham study. J Urol. Nov. 1997;158(5):1839-1844. [pmid: 9334613].
172 Nawrocki JD, Bell TJ, Lawrence WT, Ward JP. A randomized controlled trial of transurethral microwave thermotherapy. Br J Urol. 79(3):389-393. [pmid: 9117220].
173 Francisca EA, d'Ancona FC, Meuleman EJ, Debruyne FM, de la Rosette JJ. Sexual function following high energy microwave thermotherapy: results of a randomized controlled study comparing transurethral microwave thermotherapy to transurethral prostatic resection. J Urol. Feb. 1999;161(2):486-490. [pmid: 9915432].
174 D'Ancona FC, Francisca EA, Witjes WP, Welling L, Debruyne FM, De La Rosette JJ. Transurethral resection of the prostate vs high-energy thermotherapy of the prostate in patients with benign prostatic hyperplasia: long-term results. Br J Urol. Feb. 1998;81(2):259-264. [pmid: 9488070].
175 Ahmed M, Bell T, Lawrence WT, Ward JP, Watson GM. Transurethral microwave thermotherapy (Prostatron version 2.5) compared with transurethral resection of the prostate for the treatment of benign prostatic hyperplasia: a randomized, controlled, parallel study. Br J Urol. Feb. 1997;79(2):181-185. [pmid: 9052467].
176 Dahlstrand C, Walden M, Geirsson G, Pettersson S. Transurethral microwave thermotherapy versus transurethral resection for symptomatic benign prostatic obstruction: a prospective randomized study with a 2-year follow-up. Br J Urol. Nov. 1995;76(5):614-618. [pmid: 8535682].
177 Albala DM, Turk TM, Fulmer BR, Koleski F, Andriole G, Davis BE, Eure GR, Kabalin JN, Lingeman J, Nuzzarello J, Sundaram C. Periurethral transurethral microwave thermotherapy for the treatment of benign prostatic hyperplasia: an interim 1-year safety and efficacy analysis using the thermatrx TMx-2000. Tech Urol. Dec. 2000;6(4):288-293. [pmid: 11108568].
178 Wagrell L, Schelin S, Nordling J, Richthoff J, Magnusson B, Schain M, Larson T, Boyle E, Duelund J, Kroyer K, Ageheim H, Mattiasson A. Feedback microwave thermotherapy versus TURP for clinical BPH--a randomized controlled multicenter study. Urology. Aug. 2002;60(2):292-299. [pmid: 12137829].
179 Djavan B, Seitz C, Roehrborn CG, Remzi M, Fakhari M, Waldert M, Basharkhah A, Planz B, Harik M, Marberger M. Targeted transurethral microwave thermotherapy versus alpha-blockade in benign prostatic hyperplasia: outcomes at 18 months. Urology. Jan. 2001;57(1):66-70. [pmid: 11164146].
180 Floratos DL, Kiemeney LA, Rossi C, Kortmann BB, Debruyne FM, de La Rosette JJ. Long-term followup of randomized transurethral microwave thermotherapy versus transurethral prostatic resection study. J Urol. May. 2001;165(5):1533-1538. [pmid: 11342912].
181 Francisca EA, d'Ancona FC, Hendriks JC, Kiemeney LA, Debruyne FM, de La Rosette JJ. A randomized study comparing high-energy TUMT to TURP: quality-of-life results. Eur Urol. Nov. 2000;38(5):569-575. [pmid: 11096238].
182 D'Ancona FC, Francisca EA, Witjes WP, Welling L, Debruyne FM, de la Rosette JJ. High energy thermotherapy versus transurethral resection in the treatment of benign prostatic hyperplasia: results of a prospective randomized study with 1 year of followup. J Urol. Jul. 1997;158(1):120-125. [pmid: 9186336].
183 Zeitlin SI. Heat therapy in the treatment of prostatitis. Urology. Dec. 2002;60(6 Suppl):38-40. [pmid: 12521593].
184 Perlmutter AP, Verdi J, Watson GM. Prostatic heat treatments for urinary outflow obstruction. J Urol. Nov. 1993;150(5 Pt 2):1603-1606. [pmid: 7692094].
185 Montorsi F, Guazzoni G, Bergamaschi F, Consonni P, Galli L, Rigatti P. A comparison of transrectal hyperthermia, transurethral thermotherapy, urolume wallstent, and prostatic spiral for benign prostatic hyperplasia patients at poor operative risk. Prostate. 1994;24(3):156-161. [pmid: 7509486].
186 Yerushalmi A, Fishelovitz Y, Singer D, Reiner I, Arielly J, Abramovici Y, Catsenelson R, Levy E, Shani A. Localized deep microwave hyperthermia in the treatment of poor operative risk patients with benign prostatic hyperplasia. J Urol. May. 1985;133(5):873-876. [pmid: 2580997].
187 Montorsi F, Galli L, Guazzoni G, Colombo R, Bulfamante G, Barbieri L, Matozzo V, Grazioli V, Rigatti P. Transrectal microwave hyperthermia for benign prostatic hyperplasia: long-term clinical, pathological and ultrastructural patterns. J Urol. Aug. 1992;148(2 Pt 1):321-325. [pmid: 1378906].
188 Lindner A, Braf Z, Lev A, Golomb J, Leib Z, Siegel Y, Servadio C. Local hyperthermia of the prostate gland for the treatment of benign prostatic hypertrophy and urinary retention. Br J Urol. Feb. 1990;65(2):201-203. [pmid: 1690586].
189 Diagnostic and therapeutic technology assessment. Endoscopic balloon dilation of the prostate. JAMA. Feb. 26. 1992;267(8):1123-1124. 1127. 1128. [pmid: 1370964].
190 Roehrborn CG, Bartsch G, Kirby R, Andriole G, Boyle P, de la Rosette J, Perrin P, Ramsey E, Nordling J, De Campos Freire G, Arap S. Guidelines for the diagnosis and treatment of benign prostatic hyperplasia: a comparative, international overview. Urology. Nov. 2001;58(5):642-650. [pmid: 11711329].
191 Breda G, Isgro A. Treatment of benign prostatic hyperplasia with water-induced thermotherapy: experience of a single institution. J Endourol. Mar. 2002;16(2):123-126. [pmid: 11962554].
192 de la Rosette JJ, Alivizatos G, Laguna MP. Transurethral hot water balloon thermoablation. Curr Urol Rep. Aug. 2001;2(4):302-305. [pmid: 12084256].
193 Ditrolio J, Patel P, Watson RA, Irwin RJ. Chemo-ablation of the prostate with dehydrated alcohol for the treatment of prostatic obstruction. J Urol. May. 2002;167(5):2100-2103. discussion 2103-4. [pmid: 11956449].
194 Lam JS, Volpe MA, Kaplan SA. Use of prostatic stents for the treatment of benign prostatichyperplasia in high-risk patients. Curr Urol Rep. Aug. 2001;2(4):277-284. [pmid: 12084252].
195 Petas A, Isotalo T, Talja M, Tammela TL, Valimaa T, Tormala P. A randomised study to evaluate the efficacy of a biodegradable stent in the prevention of postoperative urinary retention after interstitial laser coagulation of the prostate. Scand J Urol Nephrol. Aug. 2000;34(4):262-266. [pmid: 11095085].
196 Yachia D, Aridogan IA. Comparison between first-generation (fixed-caliber) and secondgeneration (self-expanding, large caliber) temporary prostatic stents. Urol Int. 1996;57(3):165-169. [pmid: 8912445].
197 Barry MJ. Evaluation of symptoms and quality of life in men with benign prostatic hyperplasia. Urology. Dec. 2001;58(6 Suppl 1):25-32. discussion 32. [pmid: 11750246].
198 MacDiarmid SA, Goodson TC, Holmes TM, Martin PR, Doyle RB. An assessment of the comprehension of the American Urological Association Symptom Index. J Urol. Mar. 1998;159(3):873-874. [pmid: 9474172].
199 Teillac P. Relief of BPO or improvement in quality of life. Eur Urol. Suppl 2. 1998;34:3-9. [pmid: 9732823].
200 Hansen BJ, Mortensen S, Mensink HJ, Flyger H, Riehmann M, Hendolin N, Nordling J, Hald T. Comparison of the Danish Prostatic Symptom Score with the International Prostatic Symptom Score, the Madsen-Iversen and Boyarsky symptom indexes. ALFECH Study Group. Br J Urol. Jan. 1998;81(1):36-41. [pmid: 9467474].
201 Barry MJ, Fowler FJ Jr, O'Leary MP, Bruskewitz RC, Holtgrewe HL, Mebust WK. Correlation of the American Urological Association symptom index with self-administered versions of the Madsen-Iversen, Boyarsky and Maine Medical Assessment Program symptom indexes. Measurement Committee of the American Urological Association. J Urol. Nov. 1992;148(5):1558-1563. discussion 1564. [pmid: 1279219].
202 Barry MJ, Williford WO, Chang Y, Machi M, Jones KM, Walker-Corkery E, Lepor H. Benign prostatic hyperplasia specific health status measures in clinical research: how much change in the American Urological Association symptom index and the benign prostatic hyperplasia impact index is perceptible to patients?. J Urol. Nov. 1995;154(5):1770-1774. [pmid: 7563343].
203 Hansen BJ, Flyger H, Brasso K, Schou J, Nordling J, Thorup Andersen J, Mortensen S, Meyhoff HH, Walter S, Hald T. Validation of the self-administered Danish Prostatic Symptom Score (DAN-PSS-1) system for use in benign prostatic hyperplasia. Br J Urol. Oct. 1995;76(4):451-458. [pmid: 7551880].
204 Donovan JL, Abrams P, Peters TJ, Kay HE, Reynard J, Chapple C, De La Rosette JJ, Kondo A. The ICS-'BPH' Study: the psychometric validity and reliability of the ICSmale questionnaire. Br J Urol. Apr. 1996;77(4):554-562. [pmid: 8777617].
205 Roehrborn CG. Kirby RS, McConnell JD, Fitzpatrick JM, Roehrborn CG, Boyle P, editors. The placebo effect in the treatment of benign prostatic hyperplasia. Textbook of benign prostatic hyperplasia. Oxford (UK). Isis Medical Media. 1996.
206 Boyarsky S, Jones G, Paulson DF. A new look at bladder neck obstruction by the Food and Drug Administration regulators: guidelines for investigation of benign prostatic hypertrophy. Trans Am Assoc Genitourin Surg. 1977;68:29-32. [pmid: 71777].
207 Donovan JL, Peters TJ, Abrams P, Brookes ST, de aa Rosette JJ, Schafer W. Scoring the short form ICSmaleSF questionnaire. International Continence Society. J Urol. Dec. 2000;164(6):1948-1955. [pmid: 11061889].
208 Bolognese JA, Kozloff RC, Kunitz SC, Grino PB, Patrick DL, Stoner E. Validation of a symptoms questionnaire for benign prostatic hyperplasia. Prostate. 1992;21(3):247-254. [pmid: 1279647].
209 Fowler FJ Jr, Wennberg JE, Timothy RP, Barry MJ, Mulley AG Jr, Hanley D. Symptom status and quality of life following prostatectomy. JAMA. May. 27. 1988;259(20):3018-3022. [pmid: 2452905].
210 Barry MJ, Cockett AT, Holtgrewe HL, McConnell JD, Sihelnik SA, Winfield HN. Relationship of symptoms of prostatism to commonly used physiological and anatomical measures of the severity of benign prostatic hyperplasia. J Urol. Aug. 1. 1993;150(2):351-358. [pmid: 7686980].
211 van Venrooij GE, Boon TA. The value of symptom score, quality of life score, maximal urinary flow rate, residual volume and prostate size for the diagnosis of obstructive benign prostatic hyperplasia: a urodynamic analysis. J Urol. Jun. 1996;155(6):2014-2018. [pmid: 8618311].
212 Bosch JL, Hop WC, Kirkels WJ, Schroder FH. The International Prostate Symptom Score in a community-based sample of men between 55 and 74 years of age: prevalence and correlation of symptoms with age, prostate volume, flow rate and residual urine volume. Br J Urol. May. 1995;75(5):622-630. [pmid: 7542132].
213 Simpson RJ, Fisher W, Lee AJ, Russell EB, Garraway M. Benign prostatic hyperplasia in an unselected community-based population: a survey of urinary symptoms, bothersomeness and prostatic enlargement. Br J Urol. Feb. 1996;77(2):186-191. [pmid: 8800882].
214 Roberts RO, Jacobsen SJ, Jacobson DJ, Rhodes T, Girman CJ, Lieber MM. Longitudinal changes in peak urinary flow rates in a community based cohort. J Urol. Jan. 2000;163(1):107-113. [pmid: 10604326].
215 Sarma AV, Jacobsen SJ, Girman CJ, Jacobson DJ, Roberts RO, Rhodes T, Lieber M. Concomitant longitudinal changes in frequency of and bother from lower urinary tract symptoms in community dwelling men. J Urol. Oct. 2002;168(4 Pt 1):1446-1452. [pmid: 12352415].
216 Bosch JL. Urodynamic effects of various treatment modalities for benign prostatic hyperplasia. J Urol. Dec. 1997;158(6):2034-2044. [pmid: 9366308].
217 Ware JE Jr, Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. Jun. 1992;30(6):473-483. [pmid: 1593914].
218 Batista-Miranda JE, Diez MD, Bertran PA, Villavicencio H. Quality-of-life assessment in patients with benign prostatic hyperplasia: effects of various interventions. Pharmacoeconomics. 2001;19(11):1079-1090. [pmid: 11735675].
219 Patrick DL, Deyo RA. Generic and disease-specific measures in assessing health status and quality of life. Med Care. Mar. 1989;27(3 Suppl):S217-S232. [pmid: 2646490].
220 McHorney CA. Generic health measurement: past accomplishments and a measurement paradigm for the 21st century. Ann Intern Med. Oct. 15. 1997;127(8 Pt 2):743-750. [pmid: 9382391].
221 Epstein RS, Deverka PA, Chute CG, Panser L, Oesterling JE, Lieber MM, Schwartz S, Patrick D. Validation of a new quality of life questionnaire for benign prostatic hyperplasia. J Clin Epidemiol. Dec. 1992;45(12):1431-1445. [pmid: 1281223].
222 Oh BR, Kim SJ, Moon JD, Kim HN, Kwon DD, Won YH, Ryu SB, Park YI. Association of benign prostatic hyperplasia with male pattern baldness. Urology. May. 1998;51(5):744-748. [pmid: 9610587].
223 Lukacs B, Comet D, Grange JC, Thibault P. Construction and validation of a short-form benign prostatic hypertrophy health-related quality-of-life questionnaire. BPH Group in General Practice. Br J Urol. Nov. 1997;80(5):722-730. [pmid: 9393292].
224 Welch G, Weinger K, Barry MJ. Quality-of-life impact of lower urinary tract symptom severity: results from the Health Professionals Follow-up Study. Urology. Feb. 2002;59(2):245-250. [pmid: 11834396].
225 Salinas Sanchez AS, Hernandez Millan IR, Segura Martin M, Lorenzo Romero JG, Virseda Rodriguez JA. The impact of benign prostatic hyperplasia surgery on patients' quality of life. Urol Int. 2002;68(1):32-37. [pmid: 11803265].
226 Arocho R, McMillan CA, Sutton-Wallace P. Construct validation of the USA-Spanish version of the SF-36 health survey in a Cuban-American population with benign prostatic hyperplasia. Qual Life Res. Feb. 1998;7(2):121-126. [pmid: 9523493].
227 Brazier JE, Harper R, Jones NM, O'Cathain A, Thomas KJ, Usherwood T, Westlake L. Validating the SF-36 health survey questionnaire: new outcome measure for primary care. BMJ. Jul. 18. 1992;305(6846):160-164. [pmid: 1285753].
228 MacDonagh RP, Cliff AM, Speakman MJ, O'Boyle PJ, Ewings P, Gudex C. The use of generic measures of health-related quality of life in the assessment of outcome from transurethral resection of the prostate. Br J Urol. Mar. 1997;79(3):401-408. [pmid: 9117222].
229 van Agt HM, Essink-Bot ML, Krabbe PF, Bonsel GJ. Test-retest reliability of health state valuations collected with the EuroQol questionnaire. Soc Sci Med. Dec. 1994;39(11):1537-1544. [pmid: 7817218].
230 Girman CJ, Jacobsen SJ, Rhodes T, Guess HA, Roberts RO, Lieber MM. Association of healthrelated quality of life and benign prostatic enlargement. Eur Urol. Apr. 1999;35(4):277-284. [pmid: 10087388].
231 Revicki DA, Leidy NK, Howland L. Evaluating the psychometric characteristics of the Psychological General Well-Being Index with a new response scale. Qual Life Res. Aug. 1996;5(4):419-425. [pmid: 8840821].
232 Doll HA, Black NA, Flood AB, McPherson K. Criterion validation of the Nottingham HealthProfile: patient views of surgery for benign prostatic hypertrophy. Soc Sci Med. Jul. 1993;37(1):115-122. [pmid: 7687383].
233 Krongrad A, Granville LJ, Burke MA, Golden RM, Lai S, Cho L, Niederberger CS. Predictors of general quality of life in patients with benign prostate hyperplasia or prostate cancer. J Urol. Feb. 1997;157(2):534-538. [pmid: 8996350].
234 Morrow GR, Lindke J, Black P. Measurement of quality of life in patients: psychometric analyses of the Functional Living Index-Cancer (FLIC). Qual Life Res. Oct. 1992;1(5):287-296. [pmid: 1299460].
235 Stewart AL, Ware JE, Sherbourne DC, Wells KB. Stewart AL, Ware JE, editors. Psychological distress/well-being and cognitive functioning measures. Measuring functioning and well-being: the medical outcomes study approach. Durham (NC). Duke University Press. 1992:102-142.
236 Ramsey EW, Dahlstrand C. Durability of results obtained with transurethral microwave thermotherapy in the treatment of men with symptomatic benign prostatic hyperplasia. J Endourol. Oct. 2000;14(8):671-675. [pmid: 11083410].
237 Puppo P. Long-term effects on bph of medical and instrumental therapies. Eur Urol. Mar. Suppl 6. 2001;39:2-6. [pmid: 11306894].
238 Dull P, Reagan RW Jr, Bahnson RR. Managing benign prostatic hyperplasia. Am Fam Physician. Jul. 1. 2002;66(1):77-84. [pmid: 12126034].
239 Barry MJ, Mulley AG Jr, Fowler FJ, Wennberg JW. Watchful waiting vs immediate transurethral resection for symptomatic prostatism. The importance of patients' preferences. JAMA. May. 27. 1988;259(20):3010-3017. [pmid: 2452904].
240 Bisonni RS, Lawler FH, Holtgrave DR. Transurethral prostatectomy versus transurethral dilatation of the prostatic urethra for benign prostatic hyperplasia: a cost-utility analysis. Fam Pract Res J. Mar. 1993;13(1):25-36. [pmid: 7683449].
241 Blute M, Ackerman SJ, Rein AL, Beusterien K, Sullivan EM, Tanio CP, Strauss MJ, Manyak MJ. Cost effectiveness of microwave thermotherapy in patients with benign prostatic hyperplasia: part II--results. Urology. Dec. 20. 2000;56(6):981-987. [pmid: 11113744].
242 Manyak MJ, Ackerman SJ, Blute ML, Rein AL, Buesterien K, Sullivan EM, Tanio CP, Strauss MJ. Cost effectiveness of treatment for benign prostatic hyperplasia: an economic model for comparison of medical, minimally invasive, and surgical therapy. J Endourol. Feb. 2002;16(1):51-56. [pmid: 11890452].
243 Bleichrodt H, Johannesson M. Standard gamble, time trade-off and rating scale: experimental results on the ranking properties of QALYs. J Health Econ. Apr. 1997;16(2):155-175. [pmid: 10169092].
244 Cher DJ, Miyamoto J, Lenert LA. Incorporating risk attitude into Markov-process decision models: importance for individual decision making. Med Dec Making. Jul-Sep. 1997;17(3):340-350.
245 Sox HC Jr, Blatt MA, Higgins MC, Marton KI. Medical decision making. Newton (MA). Butterworth-Heinemann. 1988:406.
246 Lenert LA, Ziegler J, Lee T, Unfred C, Mahmoud R. The risks of multimedia methods: effects of actor's race and gender on preferences for health states. J Am Med Inform Assoc. Mar-Apr. 2000;7(2):177-185. [pmid: 10730601].
247 Armstrong K, Schwartz JS, Fitzgerald G, Putt M, Ubel PA. Effect of framing as gain versus loss on understanding and hypothetical treatment choices: survival and mortality curves. Med Decis Making. Jan-Feb. 2002;22(1):76-83. [pmid: 11833668].
248 Dolan P, Gudex C. Time preference, duration and health state valuations. Health Econ. Jul-Aug. 1995;4(4):289-299. [pmid: 8528431].
249 Schelin S. Mediating transurethral microwave thermotherapy by intraprostatic and periprostatic injections of mepivacaine epinephrine: effects on treatment time, energy consumption, and patient comfort. J Endourol. Mar. 2002;16(2):117-121. [pmid: 11962553].
250 Isotalo T, Talja M, Hellstrom P, Perttila I, Valimaa T, Tormala P, Tammela TL. A double-blind, randomized, placebo-controlled pilot study to investigate the effects of finasteride combined with a biodegradable self-reinforced poly L-lactic acid spiral stent in patients with urinary retention caused by bladder outlet [truncated]. BJU Int. Jul. 2001;88(1):30-34. [pmid: 11446841].
251 Wada S, Yoshimura R, Kyo M, Hase T, Masuda C, Watanabe Y, Ikemoto S, Kawashima H, Kishimoto T. Comparative study of transurethral laser prostatectomy versus transurethral electroresection for benign prostatic hyperplasia. Int J Urol. Oct. 2000;7(10):373-377. [pmid: 11144505].
252 Djavan B, Shariat S, Fakhari M, Ghawidel K, Seitz C, Partin AW, Roehrborn CG, Marberger M. Neoadjuvant and adjuvant alpha-blockade improves early results of high- energy transurethral microwave thermotherapy for lower urinary tract symptoms of benign prostatic hyperplasia: a randomized, prospective clinical trial. Urology. Feb. 1999;53(2):251-259. [pmid: 9933035].
253 Lukkarinen O, Lehtonen T, Talja M, Lundstedt S, Tiitinen J, Taari K. Finasteride following balloon dilatation of the prostate. A double-blind, placebo-controlled, multicenter study. Ann Chir Gynaecol. 1999;88(4):299-303. [pmid: 10661828].
254 Shalev M, Richter S, Kessler O, Shpitz B, Fredman B, Nissenkorn I. Long-term incidence of acute myocardial infarction after open and transurethral resection of the prostate for benign prostatic hyperplasia. J Urol. Feb. 1999;161(2):491-493. [pmid: 9915433].
255 Eliasson T, Terio H, Damber JE. Transurethral microwave thermotherapy for benign prostatic hyperplasia--experience with the Prostcare. World J Urol. 1998;16(2):109-114. [pmid: 12073223].
256 Devonec M, Dahlstrand C. Temporary urethral stenting after high-energy transurethral microwave thermotherapy of the prostate. World J Urol. 1998;16(2):120-123. [pmid: 12073225].
257 Horninger W, Janetschek G, Watson G, Reissigl A, Strasser H, Bartsch G. Are contact laser, interstitial laser, and transurethral ultrasound-guided laser-induced prostatectomy superior to transurethral prostatectomy. Prostate. Jun. 1. 1997;31(4):255-263. [pmid: 9180936].
258 Abbou CC, Colombel M, Payan C, Beurton D, Viens-Bitker C, Richard F, Gibod LB, Leduc A, Jardin A, Chatelain C, et al. . The efficacy of microwave induced hyperthermia in the treatment of BPH: the Paris public hospitals' experience. Prog Clin Biol Res. 1994;386:449-453. [pmid: 7528414].
259 de Wildt MJ, Hubregtse M, Ogden C, Carter SS, Debruyne FM, De la Rosette JJ. A 12-month study of the placebo effect in transurethral microwave thermotherapy. Br J Urol. Feb. 1996;77(2):221-227. [pmid: 8800890].
260 te Slaa E, De Wildt MJ, Debruyne FM, De Graaf R, De La Rosette JJ. Urinary tract infections following laser prostatectomy: is there a need for antibiotic prophylaxis?. Br J Urol. Feb. 1996;77(2):228-232. [pmid: 8800891].
261 Anderson TF, Bronnum-Hasen H, Sejr T, Roepstorff C. Elevated mortality following transurethral resection of the prostate for benign prostatic hypertrophy. But why?. Med Care. 1990;28:870-879. [pmid: 1700241].
262 Roos NP, Wennberg JE, Malenka DJ, Fisher ES, McPherson K, Andersen TF, Cohen MM, Ramsey E. Mortality and reoperation after open and transurethral resection of the prostate for benign prostatic hyperplasia. N Engl J Med. Apr. 27. 1989;320(17):1120-1124. [pmid: 2469015].
263 Edwards L, Powell C. An objective comparison of transurethral resection and bladder neck incision in the treatment of prostatic hypertrophy. J Urol. Aug. 1982;128(2):325-327. [pmid: 6180189].
264 Cranovsky R, Matillon Y, Banta D. EUR-ASSESS project subgroup report on coverage. Int J Technol Assess Health Care. Spring. 1997;13(2):287-332. [pmid: 9194354].
265 Krumins PE, Fihn SD, Kent DL. Symptom severity and patients' values in the decision to perform a transurethral resection of the prostate. Med Decis Making. Jan-Mar. 1988;8(1):1-8. [pmid: 2448577].
266 Llewellyn-Thomas HA, Williams JI, Levy L, Naylor CD. Using a trade-off technique to assess patients' treatment preferences for benign prostatic hyperplasia. Med Decis Making. Jul-Sep. 1996;16(3):262-282. [pmid: 8818125].