# RESULTS

## Study Characteristics

The Medline search revealed 217 abstracts of which 58 were retrieved for further analysis. Review of the bibliographies of relevant studies did not produce any additional studies. Seventeen studies were excluded because they did not contain primary data. Seven were excluded because they focused on donation to children. Three were excluded because outcomes following right lobectomy could not be discerned from outcomes following other types of surgical procedures. Five were excluded because they did not report outcomes following right lobectomy, and seven were excluded because they represented duplicate reports of previously described patients.

Nineteen studies were included in the final analysis. All were reports of individual patients, case series, or survey studies. Fourteen transplant centers published results following adult-to-adult living donor liver transplantation for 308 unique donors. Seven surveys of transplant centers in Europe, Japan, and the United States included 985 donors, some of whom may have be included in the case series

The majority of studies focused on recipient outcomes while providing only limited information regarding donor outcomes. The largest case series included 62 donors.13 The largest survey study included 449 right lobectomy donors in the United States performed as of October 2000.^22^

The quality of reports varied. Although most included some details regarding length of hospital stay and immediate complications, only a few described quality of life. Details about long-term outcomes were inconsistently included. Follow-up ranged from 1 to 13.7 months (Table 1a and 2a). However, most studies did not describe the follow-up period.

TABLE 1a Summary of Living Donor Right Lobectomy for Liver Transplantation Case Series Study Descriptions

Author | Transplantyears | Study Location | Right lobe/total LDLT | Age | Male (%) | Preoperative Testing | Mean follow-up (days)
Bak 2001^32, 37^ | 97-01 | Colorado | 41/41 | 30.8±11.2 | 63 | Physical, psychological, social examination, laboratories, MRA, cholangiography Conventional angiography if any uncertainty liver biopsy in only 3/41 | NR
Fan 2000^2, 4, 33^ | 96-99 | Hong Kong | 22/22 | Median 35.5 (range 18–51) | NR | Psychological counseling, laboratory tests, computed tomography, hepatic arteriography routine | NR
Grewal 2001^3^ | 99-00 | Tennessee | 11/11 | 36.5 (mean); reported elsewhere as 48 (range 21–41) | 55 (6/11) | History, physical examination, laboratory profile, counseling, MRI, MRA, MRCP and arteriography | NR
House 2001^38^ | 00 | Perth | 1 | 24 | 0 | History, psychosocial evaluation, laboratory tests, abdominal CT scan, angiography, ERCP, MRCP, counseling | 4 weeks
Lerut 2001^31^ | 98-00 | Belgium | 4/6 | 38 (mean) range 19–53 | 75 (3/4) | NR | NR
Marcos 2000^19^ | 98-99 | Virginia | 40/40 | 37.45 (mean) | NR | History, physical and laboratory examination, MRI, MRA, cholangiography, Pulmonary function tests, EKG, Echo, stress test, liver biopsy (except for donors to status I patients if donors had no evidence of liver disease on imaging and serology) | 254
Marcos 2001^7^ | 00-01 | Rochester, UCSF? | 48/48 | 33±7.2 | NR | History, physical and laboratory examination, MRI, MRA, cholangiography, Pulmonary function tests, EKG, Echo, stress test, liver biopsy (except for donors to status I patients if donors had no evidence of liver disease on imaging and serology) | NR
Miller 2001^34, 39, 40^ | 98-00 | New York | 50/109 | 37.9±9.6 | 62.7 | History and physical examination, cardiology and/or psychiatry clearances when indicated. Early cases imaging studies including angiography, CT, ERCP. Later cases mostly CT and/or MRI with hepatic volumetry and vascular reconstructions. MRI eventually replaced all preoperative imaging except for intraoperative cholangiography. Liver biopsies were performed for abnormal lipid profiles or history of significant alcohol use, body mass index more than 28, or imaging studies suggestive of steatosis | NR
Park 1999^41^ | 97 | Korea | 1/10 | 38 | 0/1 | History, physical, laboratory examination, ultrasonography, CT volumetry, hepatic arteriography | NR
Pomfret 2001^17^ | 98-00 | Mass | 15/15 | NR | NR | History, physical, laboratory, psychosocial examination, CT, ultrasound, celiac angiogram | NR
Sakamoto 2001^6, 13, 42^ | 94-99 | Kyoto | 62/62 | 43±11 mean, 46 median, range 21–61 | 58 | History, physical and laboratory examination. CT | At least 30 days
Sugawara 2002^43^ | 00-01 | Tokyo | 6/6 | 39 (mean), range 23–49 | 67 | History, physical examination, psychosocial evaluation, ABO blood typing, liver and kidney function tests, virus serology, determination of tumor markers, and pregnancy test for women, Doppler ultrasound, CT scan, and hepatic angiography | NR
Williams 2001^44^ | Before 2000 | London | 5/5 | Patient 1 42, patient 2 45, patient 3–5 NR | 60 | History, physical and laboratory examination. CT or MRI, angiography, MRCP | NR

TABLE 1b Summary of Living Donor Right Lobectomy for Liver Transplantation Case Series Donor Outcomes

Author | Mortality | Morbidity (%) | Complications | Hospital stay (mean days) | Readmissions | Recovery time | Functional Outcomes
Bak 2001^32, 37^ | None | NR | Bile leak with reoperation (2), bile leak with external drainage (1), incisional hernia requiring surgical repair (1), transient neurapraxia (1), drain retrieval (1), hemothorax from venous access (1), idiosyncratic medication reaction causing donor lethargy that resolved on postoperative day 3 (1) 2 required nonautologous blood transfusion | 6.3±1.6 | NR | NR | All alive and well and have returned to predonation activity. All donors returned to work.
Fan 2000^2, 4, 33^ | None | 5/22 22.7% | Staph aureus wound infection(1), incisional hernia(1), cholestasis(2), transient peroneal nerve palsy(1), biliary stricture (1), SBO(1) | 11.5 (median); range 6–38 days (5 donors stayed longer to care from recipients and their duration is included in calculation) | 1/22 for patient with SBO | NR | “All donors are well and have returned to their previous occupations” All donors returned to work.
Grewal 2001^3^ | None | 1/11 9% | Laparoscopic removal of a drain (1); “No adverse complications” 3 required transfusion | 8.8 (mean, median 9, range 7–10) | 0% | NR | “all donors are well”
House 2001^38^ | None | NR | Staphylococcal wound infection requiring 2 day readmission | 6 | 100% | NR | Returned to normal full activities within 4 weeks
Lerut 2001^31^ | None | 1/4 25% | E. coli wound infection (1) – unclear if right or left lobectomy donor | 11.2 mean (range 9–14) | NR | Resumed normal activities at median 3 weeks (range 2–4) | NR
Marcos 2000^19^ | None | 7/40 17.5% | 7 minor complications: intraoperative pressure sores (3), phlebitis (1), prolonged ileus (1) atelectasis (2). No late complications. All complications occurred in first half of LDLT experience. | 5.4 | 0% | NR | NR
Marcos 2001^7^ | None | NR | Tube thoracostomy for pneumothorax following central catheter placement (1), presumed bile leak (1) | 5.9±1.9 | 0% | NR | NR
Miller 2001^34, 39, 40^ | None | NR | Bile leak (3; none in left lobe donors) prolonged hyperbilirubinemia (1) due to an obstructed bile duct eventually resolving but left with elevated alkaline o requiring readmission (2); 2 donor operations were initiated and aborted 1 right lobe donor and 1 left lobe donor required a transfusion | 6 average stay | NR | NR | All donors are alive and well
Park 1999^41^ | None | 0% | No severe complications | NR | NR | NR | NR
Pomfret 2001^17^ | None | 9/15 67% | Morbidity 67%, Minor wound problems (5), temporary radial neuropraxia (2), symptomatic right pleural effusion (1). More serious complications: biloma requiring percutaneous drainage (2), pulmonary edema (1), portal vein thrombosis necessitating reoperation (1). No non-autologous transfusions | 8.3±.3 | NR | NR | NR
Sakamoto 2001^6, 13, 42^ | NR | 19.4% | 11 surgical complications (17.7%): 10 minor self-limited bile leaks, 1 small bowel obstruction. Separated morbidity by age of donor: age <50(n=41) 22%, >=50 14.3% | 15 median (range 9–115) | NR | NR | NR
Sugawara 2002^43^ | NR | NR | Postoperative course uneventful in all donors; no homologous blood required | 14.8 mean (range 10–24) | NR | NR | All donors returned to “previous activity levels”
Williams 2001^44^ | None | NR | None; 1 aborted donation | NR | NR | NR | NR

Table 2a Summary of Living Donor Right Lobectomy for Liver Transplantation Survey Studies

Author | Transplantyears | Study Description | Right lobe/total LDLT | Age | Male (%) | Preoperative Testing | Mean follow-up (days)
Beavers 2001^11^ | 98-00 | Donor Survey, North Carolina | 14/27 | 39 mean (27–50) | 43 | NR | 390
Brown 2001^22^ | 97-00 | Transplant Center Survey, United States | 449/449 | NR | NR | Of surveyed centers, Liver biopsy is performed routinely at 26% of centers, selectively in 60%, and none in 14%. Of surveyed centers, arteriogram is performed routinely at 60% of centers, selectively in 26% of centers, and none in 14% of centers. Of surveyed centers, ERCP is performed routinely at 5% of centers, intraoperatively routinely at 35% of centers, selectively in 10% of centers, and none in 50% of centers. | >6 months in 62%
Broelsch 2000^45^ | 96-00 | Transplant Center Survey, Europe | 111/228 | NR | NR | NR | NR
Kim-Schluger 2001^34^ | 98-00 | Donor Survey, New York | 30/48 | 40.3±9.5 | | NR | 280±157
Todo 2000^46^ | 91-99 | Transplant Center Survey, Japan | 82/308 | NR | NR | NR | NR
Trotter 2001^32^ | 97-00 | Donor Survey, Colorado | 24/24 | 33.2±11.5 | 58 | NR | 13.7 ± 8.8 months

TABLE 2b Summary of Living Donor Right Lobectomy for Liver Transplantation Survey Study Donor Outcomes

Author | Mortality | Morbidity (%) | Complications | Hospital stay (mean days) | Returned to work (%) | Months to return to work (mean) | Readmissions | Recovery time
Beavers 2001^11^ | 1 donor death from sepsis following donation surgery | 64% | Delay in return to normal bowel function (5), abdominal pain (1), incisional pain (1), blood clot (1), pleural effusion (1), sore throat (1), brachial plexus injury (1), foot paresthesias (1), “fluid between lung and liver” (1), bile leak (1), fever/elevated white count (1). 2 donor operations initiated and aborted | 9 (6–14) | 93 | NR | 29% | 18 weeks (4–52)
Brown 2001^22^ | 1 (0.2%) | Median 14% (0–100) | Biliary complications 27 (6%), reoperations 20(4%) | 6.4 (4–14) | NR | NR | 38(8%) | NR
Broelsch 2000^45^ | Did not delineate complications between right and left lobectomy: 1 donor death from multiple postoperative complications (1/123, 0.8%) | NR | Did not delineate complications between right and left lobectomy: 14% minor complications, 17.8% major complications (22 patients experienced 25 major complications); | NR | NR | NR | NR | NR
Kim-Schluger 2001^34, 39, 40^
Todo 2000^46^ | NR | NR | Do not classify between right and left lobectomy. No donor deaths. Minor to moderate complications occurred in 20 of 215 donors: Biliary leak (11), biliary stenosis (1), wound infection (3), pulmonary complication (2), portal vein thrombosis treated surgically (1) | NR | NR | NR | NR | NR
Trotter 2001^32, 37^ | None | Major 4/24 (15%) Minor 4/24 (15%) | Medical outcomes survival (24), Major (4): bile leak(2), reoperation drain retrieval(1), incisional hernia repair(1); Minor(4): GI ulcer(2),encephalopathy(1),transient neuropraxia(1); Ongoing medical treatment (1); Ongoing symptoms (17): abdominal discomfort(12), scar numbness(2), loss of appetite/nausea(2), trouble concentrating(1), poor appetite(1), weakness(4), diarrhea(1), nausea(1), back pain(1), difficulty sleeping(1) Psychosocial Outcomes: change in body image(10), scar(3), abdominal bulge(4), weight gain(2), no response(1); Relationship to recipient better(10)/worse(3)/same(18);impairment in sexual function(0);Cannot perform activity(11): afraid to drink alcohol (1), decreased ability to perform strenuous physical exertion (9), and short-term memory problems (1) | 6.3±1.5 | 96% | 2.4±1.2; 16 patients required a return to employment without full predonation duties or time for a mean time of 2.8 months | NR | 3.4 months

The following sections will review specific questions regarding living donor liver transplantation.

### Question One How many adult liver transplants have been performed in the United States from living donors? How many of these transplants have been right lobectomies?

[Literature.] A survey study of adult-to-adult living donor liver transplantation practice patterns among US transplant center reported that 449 LDLT to adults had been performed in the United States as of October 2000.^22^ The survey author assumed these to be right lobectomy donations, although details related to the type of donor procedure were not requested explicitly.22 Of 112 transplant centers in the United States, 86 completed surveys (77% response rate). Two hundred nineteen donors from the United States have been identified in published case series (Table 1a and 2a).

[UNOS.] The UNOS registry includes 37,357 liver transplants performed in the United States between 1990 and 2001, including 4,384 performed in 2001. UNOS reports 771 living donor liver transplants to adult recipients prior to October 2001(Figure 2). The number performed has increased each year, from 25 performed in 1998, 139 in 1999, 271 in 2000, to 336 LDLT performed in 2001. Because data are submitted electively by transplant centers, they are not comprehensive and do not provide uniform details regarding living donors.

Figure 2 Number of U.S. Living Donor Adult Liver Transplants : 1998 – October, 2001*

*Based on UNOS OPTN Data as of February 8, 2002

Figure 2. Number of U.S. Living Donor Adult Liver Transplants : 1998 – October, 2001*

[Experts.] Experts were unsure of the exact number of adult-to-adult right lobectomies performed worldwide. One expert estimated that it ranged from 1000 to 2000, with approximately 50% occurring in Asia (primarily Japan, Hong Kong, and Korea).23 The experts estimated that there have been approximately 400 to 500 performed in the United States, an underestimate given the UNOS registry. The experts state that virtually all living donor transplants performed in the United States involve right lobe donation.

While the number of transplant centers performing LDLT appears to be increasing, one expert speculated that the total number of LDLT performed annually at each transplant program in the United States might be decreasing.24 When a program initiates a LDLT program, approximately one-third of patients on the waiting list opt for living donation creating a back log that diminished in size as the group undergoes the procedure. As a result, when any program starts this procedure the number of living donor transplant will be high and then decrease over time. As an example, at the Medical College of Virginia approximately 45 LDLT were performed in the first 1 to 2 years after the program was initiated.24 The pace then fell to about 12 LDLT to adult recipients each year as they depleted the patients on the waiting list interested in this procedure who could find a donor. The expert believed that other centers have experienced a similar decline.

Thus, the number of LDLT that will be performed in coming years will depend upon the number of new programs beginning the procedure (apparently increasing), the output of the established programs (possibly decreasing at least in some centers), and the degree of interest in the procedure from potential donors and recipients.

[Summary] At least 771 adult-to-adult right lobe LDLT have been performed in the United States since 1997. The number performed has increased each year, from 139 in 1999, to 271 in 2000, and 336 in 2001. However, LDLT may plateau after all recipients on the waiting list for transplantation who have potential living donors undergo complete evaluation.

### Question Two How many transplant centers have performed at least one adult liver transplant from a living donor?

[Literature] A survey study of LDLT practice patterns among US transplant centers reported that 43 transplant centers had performed at least one adult-to-adult living donor liver transplantation prior to October 2000.^22^ Of 112 transplant centers in the United States, 86 completed surveys; thus, 50% of participating centers and at least 38% of all transplant centers have performed adult LDLT. Thirteen centers had performed at least 10 adult LDLT, accounting for 81% of all 449 reported procedures. The mean number of adult LDLT per center was 11, with a range from 1 to 71 transplants. Twenty-one centers had performed fewer than five adult LDLT. Of 43 programs not performing adult-to-adult LDLT, 22 planned to initiate programs within 12 months of the survey.

A report from the Living Donor Liver Transplantation Conference at The National Institutes of Health in December 2000 concluded that “the question of whether all U.S. transplant programs should perform this operation or if this complex procedure should be limited to only a few select centers needs to be established.”25 Others have suggested that a certification process should be instituted for transplant centers that are performing or intend to perform LDLT.26

[UNOS] Fifty-seven transplant centers have reported performing LDLT to adult recipients to UNOS prior to October 2001. Mean number of adult LDLT per center was 14, with a range from 1 to 99. Twenty-two centers have performed at least 10 adult LDLT, accounting for 84% of all 771 procedures. Twenty-nine centers have performed fewer than 5 LDLT.

[Experts] Five transplantation centers have experience with over 40 right lobectomies for LDLT 23 and one center has performed over 100 LDLT.24

[Summary] The number of centers performing LDLT increased to a minimum of 57 as of October 2001. Twenty-two centers have performed at least 10 adult LDLT, accounting for 84% of all 771 reported procedures.

### Question Three What protocols are used by transplant centers to follow donors for adult liver transplantation after transplantation, i.e. how long and at what frequencies are donors typically followed by the transplant center?

[Literature] Protocols used by transplant centers to follow donors for adult LDLT were not well described in the medical literature. Most case reports and series report follow-up through initial hospital discharge.

[UNOS] UNOS does not collect information regarding donor follow-up.

[Experts] At one center with one of the highest volumes of LDLT in the United States, donors are followed with MRI or CT scan and serum liver studies at 7 days, 1 month, 3 months, 6 months, and 12 months following donation surgery. 23, 27 Any evaluation beyond 12 months is on an as-needed basis. Donors are typically discharged after seven days and are reevaluated one week later.

[Summary] Protocols used by transplant centers to follow donors have not been extensively reported. In expert comments, several large volume LDLT centers follow donors serially with radiographic imaging at day 7, 1 month, 3 months, 6 months, and 12 months following either donation surgery or hospital discharge.

### Question Four What are the known morbidity and mortality rates for right lobectomy for adult-to-adult living donor liver transplantation?

a. How many adult liver donors have experienced complications from the donor procedure?
b. Describe the nature of the complications. Describe the follow-up of the donors.

[Literature] Donor outcomes are summarized by study in Tables 1b and 2b. The quality of reports varied. Length of follow-up was short, ranging from 1 to 13.7 months. However, most studies did not describe the follow-up period. Some reports described complications by incident rather than by patient; thus, the proportion of patients affected was often not provided.

Although most reports included some details regarding length of hospital stay and immediate complications, only a few described quality of life. No report included a definition of morbidity. Because what constitutes “morbidity” is not well codified, a “minor complication” as assessed by authors may seem very significant to donors.11, 28

The most serious potential consequence of a right lobectomy is death due to intraoperative or postoperative complication. Although a right lobectomy performed in a healthy donor should carry a low risk of death, the mortality rate has not been clearly established. One adult LDLT donor death was described in the medical literature.11 The donor died from sepsis during the perioperative period. A second donor death, not yet described in the medical literature, was reported in the news media January 15, 2002; the patient died three days postoperatively from aspiration after an episode of hematemesis. The hospital has been fined for negligent care, and their adult LDLT program has been suspended for six months. In a 1999 commentary, Strong stated that six persons had died as a result of liver donation29 but did not specify whether the operations were performed to obtain grafts for children or adults30 or if they were performed in the United States.

Mortality following right lobectomy in oncology is reported to be approximately 5%.8 Mortality for hepatectomy performed for nonmalignant conditions in the absence of cirrhosis or underlying liver disease is less than 1%.8 However, morbidity and mortality in the living donor should be less because of both the general better health of the donor compared with patients undergoing right hepatectomy for malignancy, and because of improvements in surgical techniques in recent years.

Donors are selected in part because of their good health. As a result, donor morbidity is an important outcome marker in determining the success of adult-to-adult LDLT. Morbidity associated with living donor right hepatic lobe donation in studies that report complications ranged from 0 to 67%, with most centers reporting less than 24% (Table 2b). Bile leak, prolonged ileus, and minor wound problems were the most commonly reported complications. Other common complications include neuropraxia (nerve injury with associated paresthesias), transient pressure sores, pleural effusions, edema, and atelectasis. Overall complication rates reported in a survey of all U.S. transplant centers ranged from 0 to 100%, with a median of 14%.22 Six percent of donors experienced biliary complications. The majority of complications were addressed conservatively, such as with endoscopic placement of a biliary stent (to treat bile leaks). An occasional patient required reoperation (Table 1b and 2b). No published reports have identified liver failure as a complication following right lobectomy.

Fourteen reports provided data on the length of hospitalization after surgery (Table 1b and 2b). The average length of hospital stay was 7.3 days. There were insufficient details provided regarding any change in length of admission as a function of procedural experience (i.e. surgical learning curve) to make general conclusions. The survey of transplant centers in the United States reported a mean hospital stay of 6.4 days (range 4 to 14 days) in 449 adult-to-adult donors.22 Seven reports that included a total of 575 donors, reported a mean hospital readmission rate of 7% (Table 1b and 2b). The United States transplant center survey reported an 8% rehospitalization rate, and reported lower rates of reoperation, rehospitalization, biliary complications, and blood transfusion in higher volume centers.22

Recovery time was described in 3 reports that included a total of 42 donors.11, 31, 32 Mean time to recovery was 14 weeks, ranging from 4 to 52 weeks. Of the 3 studies reporting return to pre-donation occupation, 58 of 60 donors were back at work.11, 32, 33 One donor was seeking job placement at the time of report.32 One donor was unable to return to work after developing chronic fatigue syndrome.11 Overall, 1 of 60 donors (2%) was unable to return to pre-donation occupation following right lobectomy. Sixty-six percent of 24 of donors required a period of light-duty work for a mean of 2.8 months before returning to full-duty work.32

Three of 19 studies included health-related quality of life as an outcome measure.11, 32, 34 Two centers used the Medical Outcomes Study 36-Item Short-Form (SF-36®), and one center used the Medical Outcomes Study 12-Item Short-Form (SF-12®). Surveys were administered at varying times from the donation. Thus, the stability of these quality of life determinations is unclear.

- In a study of 24 donors, 42% reported a change in body image, and 17% reported mild persistent symptoms, primarily abdominal discomfort, that they related to the donor surgery.32 All 24 donors would donate again if necessary, and 96% reported a benefit from the donor experience. The donor’s relationship with the recipient was the same or better in 96% of donors, and the relationship with the donor’s significant other was the same or better in 88% of donors. Mean out-of-pocket expenses incurred by donors were $3,660.
- In another study of 14 donors using the SF-12®, no significant changes were reported in physical activity, social activity, or emotional stability.11 All donors reported that they would donate again, and would recommend donation to someone in contemplation.
- A study of 30 donors reported that all living donors demonstrated significantly higher scores in general health on the SF-36 than U.S. norms.34 Donors whose recipients had no complications scored significantly higher in mental health and general health compared to U.S. norms. Donors whose recipients had major complications scored significantly lower on the mental health scale than those with recipients without major complications. Thus, donor health-related quality of life following donation surgery was less for donors whose recipients experienced major complications.

[UNOS] The United Network of Organ Sharing does not systematically track morbidity of mortality of donors. However, three donors have been listed with UNOS for liver transplantation following donation hepatectomy. Of one donor listed in 1999 and two listed in 2001, one has received a cadaveric transplant, one was removed for death prior to receiving a transplant, and one remains on the waiting list.

[Experts] Our experts were aware of two adult-to-adult donor deaths in the United States (University of North Carolina and Mt. Sinai).23, 27 In addition, they were aware of 3 adult-to-adult LDLT donor deaths in Europe (2 in Germany, 1 in France), mention of 1 possible donor death in Korea and 1 donor death in Argentina, and possible donors death in Hong Kong.23 Experts were aware of donors who required cadaveric liver transplantation following donation due to the development of liver failure but were unsure of the exact number.27 The experts emphasized that the published literature is largely from center surveys, and is likely to be biased toward favorable outcomes.35

Although not yet described, donor complications may result from the procedures used to evaluate potential donors, particularly invasive procedures such as liver biopsy and angiography. In addition, some donors will be excluded for reasons such as unforeseen anatomical abnormalities noticed intraoperatively and thus experience morbidity related to the laparotomy and scar without having actually donated.

Long-term donor outcomes are not known. Donors may ultimately experience long-term complications that have been experienced by other groups of patients undergoing major abdominal surgery such as chronic pain and small bowel obstruction related to intestinal adhesions.

[Summary] Donor mortality in the United States is estimated to be .26% (2 deaths in a total of 771 known donations to adults). In addition, three donors (.39% of all donors) were listed with UNOS for liver transplantation following donation hepatectomy due to the development of liver failure. One of these donors died prior to receiving a transplant. However, this donor death was previously described. One of the other donors received a cadaveric transplant and one remains on the UNOS waiting list. Published donor morbidity ranged from 0 to 67%, with most centers reporting less than 24%. The different rates in part reflect variations in the definitions of donor morbidity. Bile leak, prolonged ileus, and minor wound problems were the most commonly reported complications. Other common complications included neuropraxia (nerve injury with associated paresthesias), transient pressure sores, pleural effusions, edema, and atelectasis. The median complication rate reported in a survey of all US was 14%.22

Right hepatectomy donation surgery affects quality of life. In surveys of donors, mean recovery time was 3 to 4 months (range 1 to12 months). The majority of donors returned to work, although some had prolonged time away from work, and a small percentage were unable to return to work or chose to change careers. Most would donate again and recommend donation to a potential donor contemplating LDLT. One report described lasting effects on body image during a mean follow-up of 13.7 months.

### Question Five Are there identifiable donor characteristics associated with lower morbidity rates? What preoperative evaluation of living donors is necessary? Is a liver biopsy necessary in the preoperative evaluation of all living donors?

[Literature] No standard evaluation process has been identified for the preoperative evaluation of living donors. One survey of all US transplant centers reported that the median potential-donor evaluation time was 28 days (range 7 to 84).22 Minimum donor evaluation times ranged from 1 to 56 days (median 6.5 days). Approximately 45% of potential donors eventually donated (range 8 to 100%).

The donor evaluation processes described in the medical literature are summarized in Table 1a and 2a. As a general rule, the evaluation occurred in a step-wise process. In the initial evaluation, donors must be blood group (ABO) compatible and healthy, without any underlying medical condition that might compromise the safety of the donor or the health of the donated liver. Psychosocial evaluations are made to confirm informed consent and ensure that the prospective donor has adequate time to contemplate the risks of the procedure and to decline participation.1, 16, 36

Screening assessments usually include a comprehensive history and physical examination. Routine chemistries, a complete blood count, and liver enzymes and viral serologies (including evaluation for HIV and hepatitis B and C) are determined. A chest x-ray and electrocardiogram are performed. Finally, assessment of the donor anatomy for vascular and biliary variations is made using a combination of ultrasound, computed tomography (CT), magnetic resonance imaging (MRI), and arteriography. A survey of all transplant centers in the U.S. reported that 14% of programs never obtain an arteriogram, while 60% of centers obtain an arteriogram for all donors.22 Twenty-six percent of centers obtain arteriograms in selected potential donors. More extensive cardiac and pulmonary testing is performed in selected cases.

Liver biopsy is a routine part of the donor evaluation at some centers, while other programs reserve biopsy for potential donors with elevated liver enzymes or suspected steatosis (fat accumulation in the liver). The degree of steatosis has been used to correct volumetric estimates of hepatic mass estimated from imaging studies. A survey study of all U.S. transplant centers reported variable rates of liver biopsy in the routine evaluation of potential living donors.22 Fourteen percent of centers never obtained a liver biopsy, 26% obtained a liver biopsy for all donors while the remaining 60% obtained a liver biopsy only in selected cases.

No report attempted to identify donor characteristics that were associated with lower morbidity rates. However, several donor characteristics are presumed to be important for both the donor and the recipients. There is debate over the acceptability of donor livers showing steatosis; severe steatosis is generally considered to be a contraindication to donation.36 Anatomic variation can also be a reason for exclusion.6 Graft size must be sufficient to support the metabolic demand of the donor and recipient following LDLT. As a general rule, the mass of the donor liver lobe should be no less than 0.8% to 1% of the body weight of the recipient. Some programs set a minimum donor weight at 1% of body weight, while others use 0.8%.36

The donor evaluation process is not perfect. Despite extensive screening for underlying medical conditions, donors have been reported to have findings at the time of surgery that ultimately excluded the completion of donation surgery.11 For example, one donor was found to have noncaseating granulomas at the porta hepatitis after surgical incision, but prior to right lobectomy.11 Although that potential donor was included, aborted donors are generally excluded from published reports of donor outcomes because they do not undergo right lobectomy.

[UNOS] UNOS does not collect data regarding the evaluation of potential living donors.

[Experts] Experts suggest that the ideal donor candidate should be young, healthy and thin. At least two centers use an age cut-off of 50 years for the donors.23, 27 Several centers require a liver biopsy, particularly for patients with a body mass index (BMI) greater than 28. Donors with BMI greater than 35 are not accepted. Reasons for exclusion based on anatomy are handled on an individual basis. Technical refinements of the donor procedure have permitted the acceptance of donors who were once considered to be unsuitable based upon anatomic considerations.23 Figure 3 contains potential donor evaluation flow-charts from one major transplant center.

Figure 3 Stepwise Evaluation of Potential Living Donors. (a) Phase I, (b) Phase II, (c) Phase III23

Figure 3a-c. Stepwise Evaluation of Potential Living Donors. (a) Phase I, (b) Phase II, (c) Phase III23

Acceptable indications for the recipient undergoing live donor transplantation are controversial. Some transplant centers are proceeding with live donor transplants in recipients that do not meet minimal cadaveric listing criteria because they are either not sick enough or are not thought to have disease amenable to cure with transplantation (i.e., metastatic tumors or multifocal hepatocellular carcinoma).23 One expert expressed concern that until the true risk to the donor is fully understood, transplant programs should not be proceeding with live donor transplants in patients who would not ordinarily be transplant candidates just because they have a donor.23

[Summary] No standardized process exists for the evaluation of potential living donors. A step-wise evaluation to screen for medical and psychological issues is performed at most centers. Imaging studies are obtained in potential donors without medical or psychological conditions for anatomical evaluation preoperatively. Liver biopsies are performed routinely in some centers, while some centers use the biopsy selectively. In a survey study, 14% of centers never obtained a liver biopsy, 26% obtained a liver biopsy for all donors, while the remaining 60% obtained a liver biopsy only in selected cases. Liver biopsy is particularly useful in patients with a body mass index (BMI) greater than 28 to evaluate for possible steatosis. Donor characteristics associated with lower morbidity rates have not been systematically evaluated. Experts currently exclude potential donors who are over age 50 and those with BMI greater than 35. Surgical refinements in recent years have permitted the acceptance of donors with anatomic irregularities that would have precluded donation during the initial experience.