# METHODS

## Sources of Evidence

Three sources of evidence were used for this report:

1. The primary source of evidence was the published English-language literature. Abstracts from the 2001 annual meetings of the American Association for the Study of Liver Disease (AASLD) and the combined American Society of Transplantation (AST) and American Society of Transplant Surgeons (ASTS) meetings were also reviewed. These meetings represent the forums during which the majority of transplant-related studies are initially presented.
2. Registry data from United Network of Organ Sharing (UNOS).
3. Representatives from some of the major transplant programs in the United States performing LDLT.

## Published Literature

The published literature regarding right lobectomy for adult-to-adult living donor liver transplantation was identified by performing a search of the MEDLINE® database. The search was restricted to articles focusing on human subjects that were published in English between January 1995 and November 2001. Search terms included: liver transplant, liver graft, hepat graft, hepat transplant, living donors, tissue donors. A search of the meeting abstract databases identified preliminary results published at the annual meetings of the AST and ASTS (May 2001), as well as the AASLD (November 2001).

### Inclusion criteria

Studies were included that described any donor outcomes following right hepatic lobectomy for adult-to-adult living donor liver transplantation.

### Exclusion criteria

Studies were excluded if they were: published in languages other than English, focused exclusively on children (age < 18), presented outcomes following right lobectomy that could not be discerned from outcomes following left lobectomy or other donation techniques, reviewed other sources of primary patient data or represented duplicate reports of previously-described patients.

Titles and abstracts were reviewed to identify relevant articles. The bibliographies from retrieved articles were examined to identify other potentially relevant studies. All studies were examined in duplicate and consensus was achieved for all reports that were included in this evidence report based upon the inclusion and exclusion criteria described above.

Data extraction included information on the study location, patient characteristics, donation surgery, study duration, and outcomes of interest (donor morbidity, donor mortality, donor quality of life)[Appendix I: Published Literature Data Extraction Form]. Studies were categorized according to authors and transplant center to identify duplicate reports of the same patients. Duplicate reports were included if they provided additional follow-up data; however patients were counted only once. Emphasis was placed on the largest studies, and those that reported the highest quality of information.

## United Network of Organ Sharing (UNOS) Registry

Information was requested from the United Network for Organ Sharing to provide an estimate of the frequency with which living donor liver transplantation has been performed in the United States. The United Network of Organ Sharing (UNOS) under contract with the Organ Procurement and Transplantation Network (OPTN) oversees a registry that includes information on almost every cadaveric and living donor transplant recipient in the United States. Some transplant centers have electively supplied donor data as well. However, because reporting of living donor transplantation was voluntary, the information is incomplete. Furthermore, the registry contains only limited information regarding the donors. Further information about UNOS or the transplant registry can be found via the Internet at www.unos.org.

## Living Donor Liver Transplantation Expert Opinions

Current experience with donor outcomes may be incompletely reflected in the published literature. Refinements in the right-lobe donor procedure that may increase its safety continue to be described. As an example, one group reported that the adoption of specific surgical methods to optimize venous outflow resulted in a much lower rate of complications than has previously been described7; no donor complications were observed in 48 right-lobe resections and transplants. Furthermore, there appears to be a learning curve for surgeons performing the procedure suggesting that donor safety has improved since the publication of the studies included in this evidence report, most of which reflected the initial experience with LDLT. On the other hand, serious donor complications (including death and the development of post-donation liver failure) have been mentioned, but not documented in the literature or the UNOS database.

As a supplement to information provided by the literature and UNOS database, a subset of transplant surgeons and hepatologists performing LDLT was contacted to provide further insight into donor and procedure characteristics that may have a bearing on donor outcomes and provide further insight into donor adverse events [Appendix II: Expert Opinion Data Extraction Form]. Transplant surgeons and hepatologists were selected who had a large experience with LDLT and who were willing to provide information.