# BACKGROUND

The shortage of donor organs is a major limiting factor in liver transplantation. While over 5,000 transplants are performed annually in the United States, more than 1,000 candidates die each year while on the liver transplant waiting list. Approximately 18,500 patients were awaiting liver transplantation in the United States as of December 2001 according to data from the United Network for Organ Sharing (UNOS). Living donor liver transplantation (LDLT), where a healthy volunteer donates a portion of their liver, provides one means to expand organ availability. Of 4,954 liver transplants performed in 2000, 400 (8%) were from living donors.

Living donor liver transplant to pediatric recipients has been performed in the United States since 1989. Following the success of living donation in children, many transplant centers considered donation to adult recipients as a potential solution to the growing national cadaveric organ shortage.

The adult procedure is technically different from that performed in children since the volume of donor liver needed is significantly larger in adults. Donation to adults usually requires right hepatic lobectomy while donation to children is usually limited to the smaller left lateral segment (Figure 1). Right hepatic lobectomy is currently the standard procedure in the United States.

Figure 1 Normal Liver Anatomy. The liver is routinely divided into 8 separate segments, with segments 2 to 4 making up the left lobe, and segments 5 to 8 making up the right lobe. Segment 1, often known as the caudate liver, is usually excluded in LDLT. In right lobectomy segments 5 to 8 and part of 4 are donated to an adult, while segments 2 and 3 are given to a child

Figure 1. Normal Liver Anatomy. The liver is routinely divided into 8 separate segments, with segments 2 to 4 making up the left lobe, and segments 5 to 8 making up the right lobe. Segment 1, often known as the caudate liver, is usually excluded in LDLT. In right lobectomy segments 5 to 8 and part of 4 are donated to an adult, while segments 2 and 3 are given to a child.

The donor liver can be divided in a number of different ways depending on the needs of the donor and the recipient. Some programs perform a right lobectomy by removing approximately 60% of the hepatic mass, while others perform an extended right hepatectomy, removing approximately 70% of the hepatic mass, including the middle hepatic vein. Details regarding surgical techniques for adult-to-adult LDLT have been extensively reviewed elsewhere.1–6

Donor morbidity related to right lobe donation is generally considered to be higher than for left lobe donation.7–10 As a result, morbidity and mortality rates in donors undergoing these procedures are not directly comparable.11, 12

Whether right lobe donation will continue to be the standard procedure in the United States is uncertain. Recognition of the increased morbidity related to the procedure has renewed efforts to consider alternatives. A report from Japan suggested that an extended left lobe graft might be sufficient for most patients who received a right lobe graft.13 Furthermore, a case report suggested that small-for-size grafts (such as those provided by left lobe donation) may be sufficient when the transplant is performed using methods that divert excessive blood flow to the graft, which reduces venous congestion and permits better graft function and growth.14

The donor selection process involves multiple stages of evaluation beginning with a history and physical examination and proceeding to more invasive procedures. Potential donors are screened for any underlying medical or psychological disease that might compromise the safety of the donor or of the donated liver lobe. Psychosocial evaluations are made to ensure that consent is informed and free of coercion. Investigation of liver function and hepatobiliary anatomy is obtained with radiographic imaging. In some cases a liver biopsy is obtained to rule-out underlying liver disease, including fatty liver. Different centers report that about 15 to 72% of potential donors are excluded for various reasons.15–17 The most common reasons for exclusion are incompatible blood type and steatosis on liver biopsy.15 In addition, 23% never actively pursued evaluation as a potential donor after initial inquiry.

A consensus statement issued by the Live Organ Donor Consensus Group suggests that LDLT recipients should meet listing criteria for cadaveric transplantation.18 However, interpretation of this recommendation has not been uniform. Some centers restrict recipients to those with the highest probability of a favorable outcome (2b and 3 patients on the UNOS waiting list), excluding those with multiple organ failure who are on life support or those with chronic liver failure and less than seven days life expectancy (Status 1 and Status 2a patients on the UNOS waiting list).19 Other centers offer LDLT to recipients who are clearly not candidates for cadaveric transplantation by UNOS listing criteria (such as those with certain types of liver tumors). Regardless of the differences among centers, it is generally agreed that the benefit to the recipient should justify the risk to the donor. The ethics of LDLT are still hotly debated, particularly since the risk to the donor is unclear.

Medicare policy does not presently include coverage of living liver donors. Although CMS previously investigated the safety and effectiveness of the procedure for the transplant recipient, outcomes for donors were not included in the evaluation. Coverage of left lobe donors to pediatric recipients was included in that earlier report.20

The anticipated growth of adult LDLT provides a rationale for a better understanding of consequences of donors. A number of initial reports have suggested that donors may experience significant morbidity related to the procedure. A variety of complications have been described, the most common of which were bile leaks, prolonged ileus, and minor wound problems. Donors may also experience long-term consequences on quality-of-life. Donor deaths have also been reported. Thus, the purpose of this evidence report is to summarize the available evidence regarding the outcomes of donors who participated in right lobe donation for adult LDLT.

Donor outcomes would be ideally sought from a comprehensive registry. However, unlike recipient outcomes, UNOS has not systematically collected data on donor outcomes. The American Society of Transplant Surgeons has proposed a voluntary registry, which is not yet established because long-term funding has not been identified. The European Liver Transplant Registry has tracked outcomes following liver transplantation in Europe, but does not register the morbidity and mortality of donors.21 The National Institutes of Health has issued a request for applications to facilitate the systematic, prospective collection of living donor outcomes data following right lobectomy to adult recipients.