# Living Donor Liver Transplantation Expert Opinions

We gratefully acknowledge the contributions of our experts.

- Scott Cotler, M.D.
  Division of Hepatology
  Rush University
  Chicago, IL
  Scott_Cotler@rush.edu
- Elizabeth Pomfret, M.D., Ph.D.
  Director, Adult Live Donor Liver transplantation
  Lahey Clinic Medical Center
  Burlington, MA
  Elizabeth.a.pomfret@lahey.org
- Mitchell L. Shiffman, M.D.
  Medical College of Virginia
  Section Head, Hepatology
  Richmond, VA
  mshiffma@hsc.vcu.edu
- Roshan Shrestha, M.D.
  Medical Director of Liver Transplantation
  University of North Carolina at Chapel Hill
  Chapel Hill, NC
  r_shresth@med.unc.edu
- James Trotter, M.D.
  Assistant Professor Section of Hepatology University of Colorado Denver, CO
  James.Trotter@UCHSC.edu