# Expert Opinion Data Collection Form

1. Sources of data regarding donor outcomes other than the published literature:
2. Sources of data regarding the number of living donor transplants performed, the number of centers performing living donor transplant and the number of donor transplants that have been performed:
3. Any donor deaths following right lobectomy donation surgery:
4. Any donors that have required listing for emergent liver transplantation following right lobectomy:
5. Protocols that have been used by transplant centers to follow donors for adult liver transplantation after transplantation:
6. Any other pieces of information that might be useful: