# Published Data Extraction Form

Author: _______________________________________ Citation: ___________________________________________

Inclusion criteria (check if article reports the following): Exclusion criteria (check if article reports the following):

- Outcomes for adult donors of right hepatic lobes Pediatric recipients
  Report in English Review article without inclusion of primary data
  Published between 1996 and 2001 Results do not separate right lobectomy from left lobectomy donors
  No outcomes of interest reported in results Duplicate report. Includes citation:
- Location of Transplant Center: Age of Donors:
  Years of transplants reported: Sex of Donors:
  No. of right lobe donors to adults included in report: Length of Study follow-up:
  No. of left lobe donors to adults included in report: Right lobectomy procedure:
  Total number of living donors included in the report: Study design:
- MORTALITY (check one) MORBIDITY (if reported – as described by authors)
  No mortality reported Author reported complication rate:
  Mortality not stated in report Length of hospital stay:
  Mortality reported (provide details) Length of recovery:
  Need for hospital readmission:
- QUALITY OF LIFE (if reported – as described by authors)
  % donors able to return to predonation occupation:
  Length of time until return to work:
  HRQOL scores:

AUTHORS CONCLUSIONS REGARDING LIVING DONORS: