# EXECUTIVE SUMMARY

## Background

Following the success of liver transplantation in children from living donors, many transplant centers have begun performing the procedure in adults. Living donor transplantation represents a major advance in the efforts to relieve the growing national shortage of cadaveric organs.

Donation to adults usually requires a right hepatic lobectomy, a procedure that has been associated with greater morbidity compared to the left lateral segmentectomy typically used for donation to children. A variety of complications related to right hepatic lobe donation have been described, including deaths. However, the frequency and nature of complications are incompletely understood. Thus, the purpose of this evidence report is to summarize the available evidence regarding the outcomes of donors who participated in right lobe donation for adult LDLT

## Methods

The primary source of evidence was the published literature identified by performing a search of the MEDLINE® database. Studies were categorized according to transplant center and author to eliminate duplicate reports. Further information was obtained from the United Network of Organ Sharing (UNOS) and from communications with representatives from some of the transplant centers with the largest experience in adult LDLT in the United States.

## Results

Nineteen studies met inclusion criteria. All were reports of individual patients, case series, or survey studies. Fourteen transplant centers published their experience with a total of 308 unique donors. Seven studies represented surveys of transplant centers in Europe, Japan, and the United States. These included a total of 985 donors, some of whom may also have been included in the surgical series. Details regarding donor characteristics and outcomes of interest (donor morbidity, donor mortality, and donor quality of life following right lobectomy donation surgery) were reported with variable detail. Length of follow-up was relatively short, and often not stated.

Over 771 adult-to-adult LDLT have been performed in the United States according to the UNOS registry. The number performed has increased each year (from 139 in 1999, to 271 in 2000, and 336 in 2001). Virtually all LDLT performed currently in the United States involve right lobe donation. At least 57 of 122 transplant centers in the United States performed a minimum of one LDLT prior to October 2001. Twenty-two centers have performed at least 10 adult LDLT, accounting for 84% of all 771 reported procedures.

Protocols used by transplant centers to follow donors have not been extensively reported. Several large volume LDLT centers follow donors serially with radiographic imaging at day 7, 1 month, 3 months, 6 months, and 12 months following either donation surgery or hospital discharge. No donor outcomes are systematically collected at this time.

Donor mortality has been reported in two donors in the United States (providing an estimated mortality rate of .26%). In addition, three donors (.39% of all donors) were listed with UNOS for liver transplantation following donation hepatectomy due to the development of liver failure. One of these donors died prior to receiving a transplant. However, this donor death was previously described. One of the other donors received a cadaveric transplant and one remains on the UNOS waiting list. Published estimates of donor morbidity have ranged from 0 to 67%, depending in part upon how complications were defined. Bile leaks, prolonged ileus, and minor wound problems were the most commonly reported complications. A survey of all U.S. transplant centers reported a median complication rate of 14%; 6% of donors experienced biliary complications.

Right hepatectomy donation surgery has an impact on quality of life. The majority of donors returned to work. Some donors had prolonged time away from work, and a small percentage were unable to return to work or chose to change careers. In surveys of donors, mean recovery time was 3 to 4 months (range 1 to12 months). Most donors surveyed would donate again and recommend donation to a potential donor contemplating LDLT. One report described lasting effects on body image during a mean follow-up of 13.7 months.

Consensus has not been reached on the optimal evaluation process of potential living donors. A step-wise evaluation to screen for medical and psychological issues is performed at most centers. Imaging studies are obtained in potential donors without medical or psychological conditions for anatomical evaluation preoperatively. Surgical refinements in recent years have permitted the acceptance of donors with anatomic irregularities that would have precluded donation during the initial experience. Liver biopsies are performed routinely in some centers, while some centers use the biopsy selectively. Liver biopsy is particularly useful in patients with a body mass index (BMI) greater than 28 to evaluate for possible steatosis (accumulation of fat in the liver). Donor characteristics associated with lower donor morbidity rates have not been systematically evaluated. Experts currently exclude potential donors who are over age 50 and those with BMI greater than 35.

## Conclusions

Over 771 right lobectomies for LDLT to adult recipients have been performed in the United States as of October 2001, 58 percent of which have been reported in the medical literature (primarily in one transplant center survey) suggesting that the published experience has lagged significantly behind clinical experience. Donor mortality and morbidity have not been systematically collected or reported, although reasonable estimates of mortality and the most common types of perioperative complications can be derived from the available data. Increasing experience and refinements in surgical techniques may reduce the frequency of donor complications. The long-term consequences of right-lobe donation are unknown.