# REFERENCES

1 Marcos A. Right lobe living donor liver transplantation: a review. Liver Transplantation. 2000;6:3-20. [pmid: 10648573].
2 Lo CM, Fan ST, Liu CL, et al. Adult-to-adult living donor liver transplantation using extended right lobe grafts. Annals of Surgery. 1997;226:261-269. discussion 269-70. [pmid: 9339932].
3 Grewal HP, Shokouh-Amiri MH, Vera S, Stratta R, Bagous W, Gaber AO. Surgical technique for right lobe adult living donor liver transplantation without venovenous bypass or portocaval shunting and with duct-to-duct biliary reconstruction. Annals of Surgery. 2001;233:502-508. [pmid: 11303131].
4 Fan ST, Lo CM, Liu CL. Technical refinement in adult-to-adult living donor liver transplantation using right lobe graft. Annals of Surgery. 2000;231:126-131. [pmid: 10636112].
5 Marcos A, Fisher RA, Ham JM, et al. Right lobe living donor liver transplantation. Transplantation. 1999;68:798-803. [pmid: 10515380].
6 Inomata Y, Uemoto S, Asonuma K, Egawa H. Right lobe graft in living donor liver transplantation. Transplantation. 2000;69:258-264. [pmid: 10670636].
7 Marcos A, Orloff M, Mieles L, Olzinksi AT, Renz JF, Sitzman JV. Functional venous anatomy for right-lobe grafting and techniques to optimize outflow. Liver Transplantation. 2001;7:845-852. [pmid: 11679981].
8 Shapiro RS, Adams M. Ethical issues surrounding adult-to-adult living donor liver transplantation. Liver Transplantation. 2000;6:S77-S80. [pmid: 11084091].
9 Cronin DC 2nd, Millis JM, Siegler M. Transplantation of liver grafts from living donors into adults--too much, too soon. New England Journal of Medicine. 2001;344:1633-1637. [pmid: 11372018].
10 Cherqui D, Soubrane O, Husson E, et al. Laparoscopic living donor hepatectomy for liver transplantation in children. Lancet. 2002;359:392-396. [pmid: 11844509].
11 Beavers KL, Sandler RS, Fair JF, Johnson MW, Shrestha R. The living donor experience: donor health assessment and outcomes after living donor liver transplantation. Liver Transplantation. 2001;7:943-947. [pmid: 11699029].
12 Service EHTAI. Adult-to-Adult Living-Donor Liver Transplantation. Plymouth Meeting, PA. ECRI. 2001:1-29.
13 Sakamoto S, Uemoto S, Uryuhara K, et al. Graft size assessment and analysis of donors for living donor liver transplantation using right lobe. Transplantation. 2001;71:1407-1413. [pmid: 11391227].
14 Boillot O, Delafosse B, Mechet I, Boucaud C, Pouyet M. Small-for-size partial liver graft in an adult recipient a new transplant technique. Lancet. 2002;359:406-407. [pmid: 11844516].
15 Marcos A, Fisher RA, Ham JM, et al. Selection and outcome of living donors for adult to adult right lobe transplantation. Transplantation. 2000;69:2410-2415. [pmid: 10868650].
16 Trotter JF, Wachs M, Trouillot T, et al. Evaluation of 100 patients for living donor liver transplantation. Liver Transplantation. 2000;6:290-295. [pmid: 10827228].
17 Pomfret EA, Pomposelli JJ, Lewis WD, et al. Live donor adult liver transplantation using right lobe grafts: donor evaluation and surgical outcome. Archives of Surgery. 2001;136:425-433. [pmid: 11296114].
18 Abecassis M, Adams M, Adams P, et al. Consensus statement on the live organ donor. JAMA. 2000;284:2919-2926. [pmid: 11187711].
19 Marcos A, Ham JM, Fisher RA, Olzinski AT, Posner MP. Single-center analysis of the first 40 adult-to-adult living donor liver transplants using the right lobe. Liver Transplantation. 2000;6:296-301. [pmid: 10827229].
20 Hotta SS. Living Related Liver Transplantation AHCPR Pub. No. 96-0059. Rockville, MD. Agency for Health Care Policy and Research Office of Health Technology Assessment. 1996.
21 European Liver Transplant Registry. www.eltr.org.
22 Brown RS Jr, Richardson M, Lai M, Everhart JE, Russo MW, Hoofnagle J. Adult living donor liver transplantation in the US: Results of the survey from the NIH meeting. Hepatology. 2001;34:235A.
23 Pomfret E. personal communication. 2002.
24 Shiffman ML. personal communication. 2002.
25 Shiffman ML, Brown RS, Olthoff KM, et al. Living Donor Liver Transplantation: Summary of a Conference at The National Institutes of Health. Liver Transplantation. 2002;8:174-188. [pmid: 11862598].
26 Busuttil RW. How safe are donors in adult-to-adult living related liver transplantation?. Liver Transplantation. 2002;8:121-122. [pmid: 11862587].
27 Shrestha R. personal communication. 2002.
28 Beavers KL, Sandler RS, Shrestha R. Donor morbidity associated with right lobectomy for living donor liver transplantation to adult recipients: a systematic review. Liver Transplantation. 2002;8:110-117. [pmid: 11862585].
29 Strong RW. Whither living donor liver transplantation?. Liver Transplantation & Surgery. 1999;5:536-538. [pmid: 10545545].
30 Hirano I, Blei AT. Deaths after living related liver transplantation. Liver Transplantation. 2000;6:250. [pmid: 10787280].
31 Lerut JP, Ciccarelli O, Roggen FM, et al. Adult-to-adult living related liver transplantation: initial experience. Acta Gastroenterologica Belgica. 2001;64:9-14.
32 Trotter JF, Talamantes M, McClure M, et al. Right hepatic lobe donation for living donor liver transplantation: impact on donor quality of life. Liver Transplantation. 2001;7:485-493. [pmid: 11443574].
33 Fan ST, Lo CM, Liu CL, Yong BH, Chan JK, Ng IO. Safety of donors in live donor liver transplantation using right lobe grafts. Archives of Surgery. 2000;135:336-340. [pmid: 10722038].
34 Kim-Schluger L, Florman S, Schiano T, et al. Donor quality of life after adult liver transplant donation. Transplant. 2001. 2001.
35 Trotter J. personal communication. 2002.
36 Marcos A, Fisher RA, Ham JM, et al. Liver regeneration and function in donor and recipient after right lobe adult to adult living donor liver transplantation. Transplantation. 2000;69:1375-1379. [pmid: 10798757].
37 Bak T, Wachs M, Trotter J, et al. Adult-to-adult living donor liver transplantation using right-lobe grafts: results and lessons learned from a single-center experience. Liver Transplantation. 2001;7:680-686. [pmid: 11510011].
38 House AK, Jeffrey GP, Edyvane KA, et al. Adult-to-adult living donor liver transplantation for fulminant hepatic failure. Medical Journal of Australia. 2001;175:202-204. [pmid: 11587280].
39 Miller CM, Gondolesi GE, Florman S, et al. One hundred nine living donor liver transplants in adults and children: a single-center experience. Annals of Surgery. 2001;234:301-311. discussion 311-2. [pmid: 11524583].
40 Schiano TD, Kim-Schluger L, Gondolesi G, Miller CM. Adult living donor liver transplantation: the hepatologist's perspective. Hepatology. 2001;33:3-9. [pmid: 11124813].
41 Park KM, Lee SG, Lee YJ, et al. Adult-to-adult living donor liver transplantation at Asian Medical Center, Seoul, Korea. Transplantation Proceedings. 1999;31:456-458. [pmid: 10083188].
42 Fujita S, Kim ID, Uryuhara K, et al. Hepatic grafts from live donors: donor morbidity for 470 cases of live donation. Transplant International. 2000;13:333-339. [pmid: 11052268].
43 Sugawara Y, Makuuchi M, Takayama J, Imamura H, Kaneko J. Right lateral sector graft in adult living-related liver transplantation. Transplantation. 2002;73:111-114. [pmid: 11792989].
44 Williams R, Akeel A, Karani J, Rela M, Heaton N. Living related adult-to-adult liver transplantation: meeting the donor shortage. Antiviral Research. 2001;52:217-223. [pmid: 11672832].
45 Broelsch CE, Malago M, Testa G, Gamazo C. Living Donor Liver Transplantation in Adults: Outcome in Europe. Liver Transplantation. 2000;6:S64-S65. [pmid: 11084088].
46 Todo S, Furukawa H, Jin MB, Shimamura T. Living donor liver transplantation in adults: outcome in Japan. Liver Transplantation. 2000;6:S66-S72. [pmid: 11084089].