# SUMMARY

The basic concepts of chronic wound care appear to be well understood. There appears to be general consensus about the use of the basic treatment modalities for chronic wound care among authoritative bodies issuing clinical practice guidelines and opinion leaders writing surgical textbook chapters. However, their recommendations often are vague, not comprehensive, and lacking in specific details. There is also considerable variation in the frequency of reported use of treatment modalities across different types of ulcers and in the use of specific treatment modalities for specific ulcers. The findings suggest that certain elements of usual care will vary with ulcer type. Most common are offloading and debridement for diabetic ulcers and compression for venous ulcers while other treatment modalities such as cleansing and antibiotics are common to a certain degree across ulcer types. These observations are consistent with generally accepted clinical principles and based on sound pathophysiological rationales. We did not review dermatological, nursing, and podiatry textbooks. However, given the general consensus in the literature on the basic treatment modalities, it is unlikely that there will be significant variations in their recommendations.

We analyzed over 140 RCTs published from 1997 onward. The largest number of trials was found for venous ulcers, followed by diabetic ulcers and pressure ulcers. There was only one trial of arterial ischemic ulcers, so no reliable conclusions can be drawn. Dressings are universally used in all types of wounds as they were reported in about 90% of all the trials. However, saline wet-to-dry dressings were used in 50% of the diabetic ulcer trials, in 40% of the pressure ulcer trials, but in only 5% of the venous ulcer trials. Hydrocolloid dressings were used in about 40% of both venous ulcer and pressure ulcer trials but in less than 15% of the diabetic ulcer trials. As expected, the rate of compression bandage use was high (83%) in venous ulcer trials although they were also used in several diabetic ulcer trials. The rate of debridement is high (81%) in diabetic ulcer trials but mentioned in less than one-half of the venous and pressure ulcer trials. A high rate (79%) of prescribing pressure offloading was reported in diabetic ulcer trials but only in 48% of pressure ulcer trials. Cleansing was reported in 30 to 52% of trials of various wound types. The use of antibiotics was reported in about one-third of the diabetic ulcer trials and much less often in trials of other types of ulcers.

The large number of RCTs available for diabetic, pressure, and venous ulcers is deceptive in that they yielded limited information about the usual care, how different treatment modalities should be used and how they should be used in combination. Many of the trials compared one product against the product of another manufacturer (i.e., one dressing versus another dressing). Practical clinical information such as the frequency of application, or combination or sequencing of treatment modalities is generally inadequately reported in these trials.

Other than the reporting of complete wound closure, the conformance with the FDA Draft Guidance Document recommendations on outcome assessment of the 20 largest trials that we examined was low in each of the 3 wound categories of diabetic, pressure, and venous ulcers.

The quality of information provided in the RCTs of chronic wound management we examined for this report is generally poor. There is a large degree of variation in the reporting of the use of different basic wound treatment modalities. Not a single wound treatment modality, among those evaluated, was uniformly reported in all the trials. Compression bandages are considered the cornerstone treatment for venous ulcers, yet only 83% of the trials reported it as usual care in the control group. It is difficult to ascertain whether the relatively low rate of reporting of treatment modalities was indeed because the investigators did not use it as part of usual care in the trials or if the information simply was not reported. It is possible that some of these treatment modalities might have been considered to be so basic and essential to chronic wound care that the investigators did not bother to include them in their report. Over 40% of the trials did not report information about the duration of chronic wounds. Incomplete information from these trials makes it difficult to determine the reliability of these data and interpret their results.